# Results

The 100 included bodies of evidence dealt with a wide array of clinical topics employing dichotomous (n=79) and continuous (n=21) outcomes. Sample sizes of the first trials varied greatly (from 20 to 46,500 participants; median 112) and often led to wide, indeterminate confidence intervals. The pooled subsequent trials included samples from 55 to more than 280,000 participants (median 1071). Figure 2 depicts the overlap of confidence intervals between first trials and pooled subsequent trials. In 37 percent (n=37) of the comparisons statistical significance changed between first trials and pooled subsequent trials, i.e., a result that was statistically significant in the first trial was not statistically significant in the pooled subsequent trials or vice versa.

Figure 2 Overlap of confidence intervals of first trials and pooled subsequent trials

Figure 2 depicts the overlap of confidence intervals between first trials and pooled subsequent trials. In 37 percent (n=37) of the comparisons statistical significance changed between first trials (black) and pooled subsequent trials (yellow), i.e., a result that was statistically significant in the first trial was not statistically significant in the pooled subsequent trials or vice versa.

## Qualitative Concordance Analyses

Table 1 summarizes characteristics and effect estimates of the 100 pairs of first and pooled subsequent trials. Based on our criteria for concordance (see Methods), effect estimates between first and pooled subsequent trials were concordant in 36 percent of comparisons for threshold 1 which employed the strictest criteria. In other words, in 64 percent of comparisons either the statistical significance changed between first and pooled subsequent trials or the difference in point estimates was larger than a 25 percent relative risk increase or reduction (or larger than 0.2 SMD). By comparison, 50 percent of first trials were concordant with pooled subsequent trials when we applied threshold 2. Threshold 2 was more lenient than threshold 1 with respect to the magnitude of change of point estimates (50 percent relative risk increase or reduction). Forty-four percent of first trials were concordant with pooled subsequent trials when we applied threshold 3 (staggered approach).

Table 1 Characteristics and concordance of results of first trials and pooled subsequent trials

| Intervention and Outcome | First Trial | | Pooled Subsequent Trials | | Combined | P-value of Difference | Qualitative Concordance (using 3 thresholds)
| Intervention and Outcome | N | Effect Estimate (confidence interval) | N | Effect Estimate (confidence interval) | Effect Estimate (confidence interval) | P-value of Difference | Qualitative Concordance (using 3 thresholds)
Akl et al., 2011^11^ | Symptomatic VTE | 84 | RR: 0.33 (0.01 to 7.95) | 2180 | RR: 0.55 (0.37 to 0.83) | RR: 0.55 (0.37 to 82) | 0.78 | Discordant^a^ Discordant^b^ Discordant^c^
Alejandria et al., 2013^12^ | All-cause mortality | 38 | RR: 0.69 (0.18 to 2.64) | 645 | RR: 0.80 (0.27 to 2.32) | RR: 1.02 (0.81 to 1.29) | 0.88 | Concordant^a^ Concordant^b^ Discordant^c^
Amato et al., 2010^13^ | Discontinuation of treatment | 142 | RR: 0.69 (0.03 to 16.66) | 839 | RR: 1.10 (0.75 to 1.62) | RR: 1.09 (0.74 to 1.60) | 0.79 | Discordant^a^ Concordant^b^ Discordant^c^
Amato et al., 2011^14^ | Retention in treatment | 74 | RR: 0.98 (0.86 to 1.11) | 3,050 | RR: 1.03 (0.99 to 1.07) | RR: 1.02 (0.99 to 1.06) | 0.47 | Concordant^a^ Concordant^b^ Concordant^c^
Amato et al., 2011^15^ | Adverse events | 37 | RR: 0.98 (0.26 to 3.79) | 91 | RR: 1.03 (0.43 to 2.47) | RR: 1.11 (0.62 to 1.98) | 0.96 | Concordant^a^ Concordant^b^ Concordant^c^
Amato et al., 2013^16^ | Completion of treatment | 72 | RR: 1.67 (1.07 to 2.6) | 1,309 | RR: 1.06 (0.96 to 1.18) | RR: 1.08 (1.01 to 1.16) | 0.05 | Discordant^a^ Discordant^b^ Discordant^c^
Bailey et al., 2013^17^ | More than 50% pain relief | 199 | RR: 1.97 (1.46 to 2.66) | 447 | RR: 1.38 (1.21 to 1.58) | RR: 1.47 (1.29 to 1.68) | 0.03 | Discordant^a^ Discordant^b^ Discordant^c^
Bauer et al., 2011^18^ | Response to treatment | 727 | RR: 1.13 (1.07 to 1.19) | 518 | RR: 1.08 (1.01 to 1.16) | RR: 1.11 (1.06 to 1.16) | 0.31 | Concordant^a^ Concordant^b^ Concordant^c^
Bird et al., 2014^19^ | Pain-free response | 381 | RR: 4.07 (2.02 to 8.19) | 5,444 | RR: 2.94 (2.47 to 3.50) | RR: 2.99 (2.52 to 3.53) | 0.38 | Discordant^a^ Discordant^b^ Discordant^c^
Boyle et al., 2012^20^ | Systemic reaction to an insect sting | 30 | RR: 0.10 (0.01 to 0.68) | 175 | RR: 0.14 (0.04 to 0.44) | RR: 0.13 (0.05 to 0.34) | 0.80 | Concordant^a^ Concordant^b^ Concordant^c^
Braithwaite et al., 2014^21^ | Iris or retinal neo-vascularization | 98 | RR: 0.32 (0.06 to 1.84) | 838 | RR: 0.23 (0.10 to 0.53) | RR: 0.24 (0.11 to 0.52) | 0.75 | Discordant^a^ Discordant^b^ Discordant^c^
Brito et al., 2011^22^ | All-cause mortality | 326 | RR: 2.12 (0.26 to 17.32) | 6434 | RR: 0.90 (0.78 to 1.04) | RR: 0.90 (0.79 to 1.02) | 0.43 | Discordant^a^ Discordant^b^ Discordant^c^
Buchleitner et al., 2012^23^ | Mortality | 141 | RR: 0.96 (0.02 to 47.65) | 1,224 | RR: 1.19 (0.89 to 1.58) | RR: 1.19 (0.89 to 1.58) | 0.92 | Concordant^a^ Concordant^b^ Concordant^c^
Cates et al., 2012^24^ | Serious adverse events | 204 | RR: 0.20 (0.01 to 4.04) | 6442 | RR: 1.56 (0.99 to 2.45) | RR: 1.49 (0.96 to 2.33) | 0.19 | Discordant^a^ Discordant^b^ Discordant^c^
Cates et al., 2013^25^ | Final rise in FEV | 53 | SMD: -0.05 (-0.59 to 0.49) | 254 | SMD: 0.07 (-0.17 to 0.32) | SMD: 0.05 (-0.17 to 0.28) | 0.69 | Concordant^a^ Concordant^b^ Concordant^c^
Charoenkwan et al., 2014^26^ | Febrile morbidity | 100 | RR: 0.72 (0.17 to 3.06) | 471 | RR: 2.21 (0.95 to 5.17) | RR: 1.66 (0.80 to 3.45) | 0.19 | Discordant^a^ Discordant^b^ Discordant^c^
Chauhan et al., 2014^27^ | Exacerbations requiring corticosteroids | 429 | RR: 0.3 (0.08 to 1.09) | 5,494 | RR: 0.89 (0.78 to 1.02) | RR: 0.88 (0.77 to 1.01) | 0.10 | Discordant^a^ Discordant^b^ Discordant^c^
Chin et al., 2013^28^ | Supple-mental local anesthetic blocks | 40 | RR: 1,06 (0.84 to 1.34) | 821 | RR: 1,02 (0.95 to 1.1) | RR: 1.03 (0.96 to 1.10) | 0.77 | Concordant^a^ Concordant^b^ Concordant^c^
Cho et al., 2014^29^ | Urine volume | 90 | SMD: 0.18 (-0.23 to 0.60) | 430 | SMD: 0.27 (-0.02 to 0.55) | SMD: 0.25 (0.02 to 0.49) | 0.71 | Concordant^a^ Concordant^b^ Concordant^c^
Chong et al., 2013^30^ | Exacerbations | 700 | RR: 1.01 (0.82 to 1.24) | 4,828 | RR: 0.83 (0.78 to 0.88) | RR: 0.84 (0.79 to 0.89) | 0.07 | Discordant^a^ Discordant^b^ Discordant^c^
Clarke et al., 2014^31^ | At least 50% of maximum pain relief | 125 | RR: 6.08 (2.09 to 17.70) | 673 | RR: 5.04 (2.95 to 8.62) | RR: 5.08 (3.20 to 8.05) | 0.77 | Discordant^a^ Discordant^b^ Discordant^c^
Clifford et al., 2012^32^ | Left- ventricular ejection fraction | 40 | SMD: 0.48 (-0.15 to 1.11) | 839 | SMD: 0.27 (-0.01 to 0.54) | SMD: 0.28 (0.02 to 0.54) | 0.55 | Discordant^a^ Concordant^b^ Concordant^c^
Costi et al., 2014^33^ | Agitation | 133 | RR: 0.07 (0.01 to 0.49) | 1114 | RR: 0.39 (0.29 to 0.51) | RR: 0.37 (0.28 to 0.50) | 0.09 | Discordant^a^ Concordant^b^ Concordant^c^
Eftimov et al., 2013^34^ | Significant improvement in disability score | 28 | RR: 1.16 (0.32 to 4.24) | 170 | RR: 2.37 (1.69 to 3.33) | RR: 2.26 (1.63 to 3.15) | 0.30 | Discordant^a^ Discordant^b^ Discordant^c^
Feagan et al., 2012^35^ | Failure to maintain remission | 57 | RR: 1.09 (0.39 to 3.04) | 1,598 | RR: 1.12 (0.98 to 1.28) | RR: 1.12 (0.99 to 1.27) | 0.96 | Concordant^a^ Concordant^b^ Concordant^c^
Fernandes et al., 2013^36^ | Length of hospital stay | 29 | SMD: -0.3 (-1.03 to 0.43) | 614 | SMD: -0.14 (-0.37 to 0.09) | SMD: -0.15 (-0.36 to 0.06) | 0.69 | Concordant^a^ Concordant^b^ Concordant^c^
Fransen et al., 2014^37^ | Pain | 68 | SMD: -0.73 (-1.22 to -0.24) | 451 | SMD: -0.33 (-0.52 to -0.15) | SMD: -0.38 (-0.55 to -0.21) | 0.12 | Discordant^a^ Concordant^b^ Concordant^c^
Fullerton et al., 2014^38^ | Manifestation of neuropathy | 539 | RR: 0.29 (0.13 to 0.66) | 664 | RR: 0.37 (0.23 to 0.59) | RR: 0.35 (0.23 to 0.53) | 0.62 | Concordant^a^ Concordant^b^ Concordant^c^
Gafter et al., 2012^39^ | Mortality | 52 | RR: 1.27 (0.49 to 3.24) | 219 | RR: 0.69 (0.56 to 0.86) | RR: 0.71 (0.57 to 0.88) | 0.22 | Discordant^a^ Discordant^b^ Discordant^c^
Gogtay et al. 2013^40^ | Remaining parasitaemic after 24 hours | 180 | RR: 0.20 (0.08 to 0.50) | 1,472 | RR: 0.43 (0.38 to 0.50) | RR: 0.42 (0.36 to 0.49) | 0.11 | Concordant^a^ Concordant^b^ Concordant^c^
Gowing et al., 2009^41^ | Withdrawal from treatment | 72 | RR: 1.12 (0.77 to 1.61) | 409 | RR: 1.69 (1.35 to 2.1) | RR: 1.61 (1.31 to 1.99) | 0.06 | Discordant^a^ Discordant^b^ Discordant^c^
Griffiths et al., 2013^42^ | Hospital admission | 31 | RR: 0.94 (0.06 to 13.82) | 1,967 | RR: 0.74 (0.64 to 0.85) | RR: 0.735 (0.64 to 0.85) | 0.87 | Discordant^a^ Discordant^b^ Discordant^c^
Gurion et al., 2012^43^ | Mortality | 388 | RR: 1.09 (0.99 to 1.2) | 3,017 | RR: 1.01 (0.96 to 1.06) | RR: 1.02 (0.98 to 1.07) | 0.17 | Concordant^a^ Concordant^b^ Concordant^c^
Hahn et al., 2014^44^ | Adverse events due to hypertension | 181 | RR: 0.77 (0.41 to 1.45) | 1160 | RR: 0.97 (0.66 to 1.43) | RR: 0.93 (0.69 to 1.26) | 0.55 | Concordant^a^ Concordant^b^ Concordant^c^
Häuser et al., 2013^45^ | Withdrawals due to adverse events | 207 | RR: 1.62 (0.81 to 3.26) | 1,734 | RR: 1.84 (1.52 to 2.22) | RR: 1.83 (1.53 to 2.18) | 0.74 | Discordant^a^ Discordant^b^ Discordant^c^
Hayward et al., 2012^46^ | Reduction in sore throat pain at 24 hours | 58 | SMD: 0.70 (0.17 to 1.24) | 559 | SMD: 0.47 (0.18 to 0.75) | SMD: 0.49 (0.24 to 0.75) | 0.44 | Discordant^a^ Concordant^b^ Concordant^c^
Hemmingsen et al., 2013^47^ | Hypoglycemia | 153 | RR: 2.6 (0.52 to 12.99) | 27,974 | RR: 1.98 (1.36 to 2.86) | RR: 2.01 (1.41 to 2.86) | 0.76 | Discordant^a^ Discordant^b^ Discordant^c^
Hoare et al., 2010^48^ | Quality of movement | 29 | SMD: 0.56 (-0.18 to 1.30) | 55 | SMD: 0.91 (0.13 to 1.68) | SMD: 0.81 (0.31 to 1.31) | 0.52 | Discordant^a^ Discordant^b^ Discordant^c^
Hodson et al., 2013^49^ | Cytomegalovirus infections | 104 | RR: 0.26 (0.09 to 0.72) | 1,005 | RR: 0.43 (0.35 to 0.52) | RR: 0.42 (0.32 to 0.56) | 0.34 | Concordant^a^ Concordant^b^ Concordant^c^
Holme et al., 2013^50^ | All-cause Mortality | 46551 | RR: 1.0 (0.97 to 1.02) | 28,3091 | RR: 1.0 (0.99 to 1.01) | RR: 1.00 (0.99 to 1.01) | 1.00 | Concordant^a^ Concordant^b^ Concordant^c^
Horey et al., 2013^51^ | Preferred and actual mode of birth | 1192 | RR: 1.01 (0.96 to 1.08) | 729 | RR: 1.02 (0.92 to 1.13) | RR: 1.02 (0.96 to 1.07) | 0.88 | Concordant^a^ Concordant^b^ Concordant^c^
Howe et al., 2011^52^ | Change in bone mineral density | 49 | SMD: 0.1 (0.46 to 0.67) | 766 | SMD: 0.22 (0.05 to 0.40) | SMD: 0.22 (0.06 to 0.38) | 0.70 | Discordant^a^ Discordant^b^ Discordant^c^
Hughes et al., 2014^53^ | Discontinuation of treatment | 147 | RR: 0.04 (0.0 to 0.65) | 348 | RR: 0.25 (0.08 to 0.78) | RR: 0.20 (0.06 to 0.65) | 0.30 | Discordant^a^ Discordant^b^ Discordant^c^
Irving et al., 2012^54^ | Clinically apparent hepatitis A | 1037 | RR: 0.19 (0.08 to 0.42) | 40,393 | RR: 0.05 (0.01 to 0.17) | RR: 0.10 (0.03 to 0.29) | 0.11 | Concordant^a^ Concordant^b^ Concordant^c^
Itchaki et al., 2013^55^ | Disease control | 143 | RR: 0.90 (0.59 to 1.36) | 616 | RR: 0.90 (0.65 to 1.25) | RR: 0.89 (0.69 to 1.14) | 1.00 | Concordant^a^ Concordant^b^ Concordant^c^
Karner et al., 2014^56^ | Improvement in quality of life | 921 | RR: 1.64 (1.36 to 1.98) | 15,866 | RR: 1.23 (1.18 to 1.29) | RR: 1.26 (1.19 to 1.33) | 0.00 | Discordant^a^ Concordant^b^ Discordant^c^
Katalinic et al., 2010^57^ | Joint mobility | 28 | SMD: 0.00 (-0.74 to 0.74) | 109 | SMD: 0.27 (-0.1 to 0.64) | SMD: 0.24 (-0.08 to 0.57) | 0.52 | Discordant^a^ Concordant^b^ Concordant^c^
Kew Kayleigh et al., 2013^58^ | Exacerbations requiring oral steroids | 2135 | RR: 0.83 (0.67 to 1.03) | 3,975 | RR: 0.74 (0.63 to 0.88) | RR: 0.79 (0.69 to 0.91) | 0.42 | Discordant^a^ Discordant^b^ Discordant^c^
Kew Kayleigh et al., 2014^59^ | Withdrawals | 281 | RR: 0.69 (0.40 to 1.18) | 7,946 | RR: 0.87 (0.84 to 0.91) | RR: 0.87 (0.84 to 0.91) | 0.41 | Discordant^a^ Discordant^b^ Discordant^c^
Koretz et al., 2013^60^ | Variceal bleeding | 1,050 | RR: 0.52 (0.13 to 2.05) | 662 | RR: 0.14 (0.03 to 0.73) | RR: 0.30 (0.10 to 0.88) | 0.22 | Discordant^a^ Discordant^b^ Discordant^c^
Kramer et al., 2014^61^ | Parasitological failure- | 59 | RR: 0.18 (0.08 to 0.39) | 805 | RR: 0.45 (0.33 to 0.62) | RR: 0.42 (0.29 to 0.59) | 0.03 | Discordant^a^ Concordant^b^ Discordant^c^
Kruis et al., 2013^62^ | Hospital days per patient | 50 | SMD: 0.29 (-0.27 to 0.84) | 691 | SMD: -0.51 (-0.72 to -0.30) | SMD: -0.42 (-0.68 to -0.15) | 0.01 | Discordant^a^ Discordant^b^ Discordant^c^
Kumar et al., 2011^63^ | Duration of phototherapy-hours | 69 | SMD: -0.06 (-0.53 to 0.41) | 223 | SMD: -0.24 (-0.60 to 0.12) | SMD: -0.21 (-0.52 to 0.10) | 0.52 | Concordant^a^ Concordant^b^ Concordant^c^
La Mantia et al., 2012^64^ | Sustained EDSS increase | 502 | RR: 0.83 (0.69 to 0.99) | 604 | RR: 1.0 (0.73 to 1.35) | RR: 0.90 (0.75 to 1.08) | 0.31 | Discordant^a^ Discordant^b^ Discordant^c^
Lai et al., 2013^65^ | Adverse effects | 49 | RR: 2.04 (0.74 to 5.61) | 2,954 | RR: 1.08 (0.93 to 1.25) | RR: 1.09 (0.94 to 1.27) | 0.23 | Discordant^a^ Discordant^b^ Discordant^c^
Law et al., 2013^66^ | Pain after 2 hours | 576 | RR: 3.09 (2.34 to 4.07) | 2,819 | RR: 2.62 (2.18 to 3.14) | RR: 2.69 (2.29 to 3.15) | 0.33 | Discordant^a^ Concordant^b^ Concordant^c^
Lazzerini et al., 2013^67^ | Adverse events | 50 | RR: 1.0 (0.02 to 48.49) | 2290 | RR: 1.56 (1.32 to 1.85) | RR: 1.56 (1.31 to 1.85) | 0.83 | Discordant^a^ Discordant^b^ Discordant^c^
Lemiengre et al., 2012^68^ | Treatment failure | 192 | RR: 1.41 (0.11 to 1.54) | 2,175 | RR: 0.55 (0.41 to 0.76) | RR: 0.55 (0.40 to 0.74) | 0.68 | Discordant^a^ Discordant^b^ Discordant^c^
Lewis et al., 2013^69^ | Vomiting | 183 | RR: 0.75 (0.52 to 1.07) | 883 | RR: 0.73 (0.57 to 0.94) | RR: 0.74 (0.60 to 0.91) | 0.91 | Discordant^a^ Discordant^b^ Discordant^c^
Li et al., 2014^70^ | Withdrawal due to adverse effects. | 501 | RR: 0.62 (0.40 to 0.96) | 802 | RR: 0.84 (0.74 to 0.96) | RR: 0.77 (0.63 to 0.95) | 0.19 | Concordant^a^ Concordant^b^ Concordant^c^
Liakopoulos et al., 2012^71^ | Length of stay in hospital | 40 | SMD:0.04 (-0.41 to 0.48) | 837 | SMD: -0.35 (-0.61 to -0.1) | SMD: -0.31 (-0.55 to -0.07) | 0.11 | Discordant^a^ Discordant^b^ Discordant^c^
Lopez-Olivo et al., 2014^72^ | Adverse events | 35 | RR: 3.17 (0.14 to 72.77) | 578 | RR: 2.00 (1.25 to 3.19) | RR: 2.02 (1.27 to 3.20) | 0.79 | Discordant^a^ Discordant^b^ Discordant^c^
Main et al., 2013^73^ | Stroke | 2,763 | RR: 1.11 (0.85 to 1.44) | 30,434 | RR: 1.30 (1.12 to 1.50) | RR: 1.25 (1.10 to 1.42) | 0.31 | Discordant^a^ Discordant^b^ Discordant^c^
Manheimer et al., 2010^74^ | Function | 284 | SMD: -0.20 (-0.44 to 0.03) | 1,114 | SMD: -0.09 (-0.21 to 0.04) | SMD: -0.11 (-0.22—0.01) | 0.38 | Concordant^a^ Concordant^b^ Concordant^c^
Massel et al., 2013^75^ | Thromboembolism | 163 | RR: 0.35 (0.12 to 1.05) | 3,959 | RR: 0.48 (0.35 to 0.65) | RR: 0.48 (0.36 to 0.64) | 0.60 | Discordant^a^ Discordant^b^ Discordant^c^
Middeldorp et al., 2014^76^ | Incidence of recurrent VTE | 214 | RR: 0.11 (0.01 to 0.83) | 3,322 | RR: 0.22 (0.12 to 0.40) | RR: 0.21 (0.12 to 0.37) | 0.56 | Concordant^a^ Concordant^b^ Concordant^c^
Moja et al., 2012^77^ | Congestive heart failure | 1,804 | RR: 3.64 (1.76 to 7.53) | 8,477 | RR: 5.43 (2.42 to 12.17) | RR: 4.88 (2.64 to 9.04) | 0.48 | Discordant^a^ Discordant^b^ Discordant^c^
Mössler et al., 2011^78^ | Mental state: Negative symptoms | 76 | SMD: -1.08 (-1.56 to -0.60) | 164 | SMD: -0.57 (-1.03 to -0.12) | SMD: -0.71 (-1.11 to -0.32) | 0.09 | Discordant^a^ Discordant^b^ Discordant^c^
Musini et al., 2014^79^ | Systolic blood pressure | 90 | SMD: -1.08 (-1.54 to -0.62) | 2,555 | SMD: -0.48 (-0.56 to -0.40) | SMD: -0.50 (-0.58 to -0.42) | 0.06 | Discordant^a^ Discordant^b^ Discordant^c^
Musini et al., 2009^80^ | Cardiovascular morbidity and mortality | 81 | RR: 0.41 (0.22 to 0.76) | 23,013 | RR: 0.75 (0.66 to 0.85) | RR: 0.74 (0.65 to 0.84) | 0.01 | Discordant^a^ Concordant^b^ Concordant^c^
Nannini et al., 2013^81^ | Mortality | 3,067 | RR: 0.79 (0.66 to 0.93) | 4,456 | RR: 1.02 (0.58 to 1.79) | RR: 0.80 (0.68 to 0.95) | 0.40 | Discordant^a^ Discordant^b^ Discordant^c^
Nelson et al., 2011^82^ | Persistence of the anal fissure | 28 | RR: 1.0 (0.02 to 47.08) | 308 | RR: 0.98 (0.42 to 2.33) | RR: 0.98 (0.42 to 2.28) | 0.99 | Concordant^a^ Concordant^b^ Concordant^c^
Nelson et al., 2012^83^ | Healing | 24 | RR: 0.2 (0.01 to 3.76) | 955 | RR: 0.24 (0.15 to 0.4) | RR: 0.24 (0.15 to 0.40) | 0.91 | Discordant^a^ Discordant^b^ Discordant^c^
Nelson et al., 2014^84^ | Surgical wound infection | 83 | RR: 0.57 (0.29 to 1.13) | 2,372 | RR: 0.34 (0.28 to 0.41) | RR: 0.35 (0.29 to 0.41) | 0.15 | Discordant^a^ Discordant^b^ Discordant^c^
Nüesch et al., 2010^85^ | Withdrawal because of adverse events | 115 | RR: 3.61 (1.95 to 6.71) | 2,247 | RR: 4.21 (3.03 to 5.84) | RR: 3.96 (3.02 to 5.17) | 0.68 | Discordant^a^ Discordant^b^ Discordant^c^
Nussbaum et al., 2012^86^ | Leaving the study early- any reason | 247 | RR: 0.59 (0.46 to 0.75) | 1936 | RR: 0.79 (0.71 to 0.87) | RR: 0.75 (0.66 to 0.86) | 0.03 | Concordant^a^ Concordant^b^ Concordant^c^
Pandian et al., 2013^87^ | Multiple pregnancy rate | 53 | RR: 5.78 (0.75 to 44.76) | 1,411 | RR: 6.94 (2.39 to 20.13) | RR: 6.55 (2.61 to 16.45) | 0.89 | Discordant^a^ Discordant^b^ Discordant^c^
Pani et al., 2011^88^ | Antidepressants and alcohol abstinence | 20 | RR: 1.5 (0.87 to 2.59) | 922 | RR: 1.25 (0.88 to 1.79) | RR: 1.28 (0.95 to 1.73) | 0.60 | Discordant^a^ Concordant^b^ Discordant^c^
Paul et al., 2013^89^ | Mortality | 104 | RR: 0.96 (0.4 to 2.29) | 1,614 | RR: 0.89 (0.75 to 1.05) | RR: 0.89 (0.76 to 1.05) | 0.88 | Discordant^a^ Concordant^b^ Discordant^c^
Perez et al., 2009^90^ | Mortality | 38 | RR: 0.3 (0.01 to 6.94) | 84,273 | RR: 0.93 (0.88 to 0.98) | RR: 0.93 (0.88 to 0.98) | 0.51 | Discordant^a^ Discordant^b^ Discordant^c^
Rajaram et al., 2013^91^ | Hospital length of stay | 88 | SMD: 0.04 (-0.40 to 0.48) | 415 | SMD: 0.18 (-0.02 to 0.38) | SMD: 0.15 (-0.03 to 0.34) | 0.56 | Concordant^a^ Concordant^b^ Concordant^c^
Rehman et al., 2011^92^ | Incontinence | 142 | RR: 0.74 (0.31 to 1.75) | 292 | RR: 1.00 (0.81 to 1.24) | RR: 0.98 (0.80 to 1.21) | 0.52 | Discordant^a^ Concordant^b^ Discordant^c^
Richards et al., 2013^93^ | Physical activity as dichotomous outcome | 329 | RR: 1.18 (0.80 to 1.76) | 2,948 | RR: 1.35 (0.82 to 2.2) | RR: 1.25 (0.95 to 1.65) | 0.69 | Concordant^a^ Concordant^b^ Concordant^c^
Rubinstein et al., 2011^94^ | Functional status | 54 | SMD: -0.18 (-0.73 to 0.36) | 1,364 | SMD: -0.05 (-0.16 to 0.06) | SMD: -0.06 (-0.16 to 0.05) | 0.66 | Concordant^a^ Concordant^b^ Concordant^c^
Santa Cruz et al., 2013^95^ | Mortality before hospital discharge | 549 | RR: 0.91 (0.69 to 1.21) | 1,750 | RR: 0.90 (0.80 to 1.02) | RR: 0.90 (0.81 to 1.01) | 0.95 | Concordant^a^ Concordant^b^ Concordant^c^
Shepperd et al., 2011^96^ | Dying at home | 310 | RR: 1.39 (1.16 to 1.67) | 342 | RR: 1.19 (0.92 to 1.55) | RR: 1.32 (1.14 to 1.54) | 0.34 | Discordant^a^ Discordant^b^ Discordant^c^
Sinclair et al., 2011^97^ | Rate of cholera | 5,582 | RR: 0.30 (0.20 to 0.44) | 23,423 | RR: 0.36 (0.26 to 0.48) | RR: 0.34 (0.27 to 0.43) | 0.48 | Concordant^a^ Concordant^b^ Concordant^c^
Soares-Weiser et al., 2012^98^ | Severe rotavirus diarrhea | 215 | RR: 0.22 (0.05 to 1.0) | 40,416 | RR: 0.13 (0.07 to 0.26) | RR: 0.14 (0.08 to 0.26) | 0.54 | Concordant^a^ Concordant^b^ Concordant^c^
Solomon et al., 2014^99^ | Loss of fewer than 15 letters visual acuity | 22 | RR: 1.19 (0.84 to 1.68) | 2,424 | RR: 1.0 (0.98 to 1.02) | RR: 1.00 (0.98 to 1.02) | 0.33 | Concordant^a^ Concordant^b^ Concordant^c^
Spinks et al., 2013^100^ | Incidence of otitis media | 506 | RR: 0.23 (0.01 to 4.67) | 3,254 | RR: 0.33 (0.17 to 0.62) | RR: 0.32 (0.17 to 0.61) | 0.83 | Discordant^a^ Discordant^b^ Discordant^c^
Swinnen et al., 2011^101^ | Weight gain | 319 | SMD: -0.23 (-0.46 to 0.01) | 1,931 | SMD: -0.26 (-0.35 to -0.16) | SMD: -0.25 (-0.34 to -0.17) | 0.82 | Discordant^a^ Discordant^b^ Discordant^c^
Tacklind et al., 2012^102^ | Peak urine flow | 85 | SMD: -0.08 (-0.51 to 0.34) | 582 | SMD: 0.11 (-0.05 to 0.27) | SMD: 0.09 (-0.06 to 0.24) | 0.40 | Concordant^a^ Concordant^b^ Concordant^c^
Tangsiriwatthana et al., 2013^103^ | Pain | 52 | SMD: -0.13 (-0.68 to 0.41) | 329 | SMD: -0.47 (-0.87 to -0.06) | SMD: -0.40 (-0.73 to -0.07) | 0.29 | Discordant^a^ Discordant^b^ Discordant^c^
Thomas et al., 2014^104^ | Caesarean section | 80 | RR: 0.50 (0.21 to 1.20) | 966 | RR: 0.97 (0.75 to 1.26) | RR: 0.92 (0.72 to 1.18) | 0.15 | Discordant^a^ Concordant^b^ Discordant^c^
Torrego et al., 2014^105^ | Hospital admissions | 109 | RR: 1.96 (0.38 to 10.28) | 320 | RR: 4.97 (1.37 to 18.08) | RR: 3.50 (1.26 to 9.68) | 0.39 | Discordant^a^ Discordant^b^ Discordant^c^
Venekamp et al., 2013^106^ | Vomiting, diarrhoea or rash | 149 | RR: 3.21 (0.34 to 30.14) | 1,874 | RR: 1.36 (1.17 to 1.57) | RR: 1.34 (1.16 to 1.55) | 0.46 | Discordant^a^ Discordant^b^ Discordant^c^
Webster et al., 2013^107^ | Catheter-related blood stream infection | 206 | RR: 1.0 (0.02 to 49.92) | 4,600 | RR: 0.73 (0.14 to 3.89) | RR: 0.77 (0.17 to 3.57) | 0.89 | Discordant^a^ Concordant^b^ Discordant^c^
Wilhelmus et al., 2010^108^ | Healing of herpes simplex virus keratitis | 70 | RR: 1.20 (0.96 to 1.50) | 331 | RR: 2.1 (1.44 to 3.08) | RR: 1.86 (1.35 to 2,54) | 0.01 | Discordant^a^ Discordant^b^ Discordant^c^
Yeoh et al., 2012^109^ | Blood lead level | 95 | SMD: -0.03 (-0.43 to 0.37) | 720 | SMD: 0.02 (-0.13 to 0.17) | SMD: 0.01 (-0.12 to 0.15) | 0.82 | Concordant^a^ Concordant^b^ Concordant^c^
Yuan et al., 2014^110^ | Mortality | 194 | RR: 1.00 (0.21 to 4.83) | 439 | RR: 1.50 (0.43 to 5.23) | RR: 1.28 (0.49 to 3.39) | 0.70 | Discordant^a^ Discordant^b^ Discordant^c^

EDSS = Expanded Disability Status Scale; FEV = forced expiratory volume; RR = relative risk; SMD = standardized mean difference; VTE = venous thromboembolism

Concordance was defined as:

a No change in statistical significance; relative change in magnitude of effects <25 percent (<0.2 SMDs for continuous outcomes)

b No change in statistical significance; relative change in magnitude of effects <50 percent (<0.5 SMDs for continuous outcomes)

c No change in statistical significance and,

-- relative change in magnitude of effects <25 percent (<0.2 SMDs for continuous outcomes) for small treatment effects, or
-- relative change in magnitude of effects <50 percent (<0.2 SMDs for continuous outcomes) for large treatment effects, or
-- relative change in magnitude of effects <10 percent for extremely patient-relevant outcomes.

## Quantitative Concordance and Differences in Magnitudes of Effect Estimates

The concordance correlation between the point estimates of first trials and point estimates of the pooled subsequent trials was high (rho 0.78, where 1 indicates perfect concordance). When we took the variance of estimates into consideration (z-scores), the correlation coefficient decreased; however, estimates from first and pooled subsequent trials were still strongly correlated (rho 0.64).

We also set out to determine differences in the magnitudes of effect estimates between first trials and pooled subsequent trials using ratios of relative risks and SMDs as the outcome measures. Seven percent of comparisons revealed statistically significant differences between effect estimates of first trials and those of the pooled subsequent trials (see Table 1).

Based on a random effects meta-analysis, the mean difference between estimates of first trials and pooled subsequent trials was 0.16 SMD (95% CI, 0.12 to 0.21; Figure 3); the median was 0.21 SMD (interquartile range: 0.13 to 0.45).

Figure 3 Meta-analysis of differences of effect estimates between first and pooled subsequent trials

Based on a random effects meta-analysis, the mean difference between estimates of first trials and pooled subsequent trials was 0.16 SMD (95% CI, 0.12 to 0.21); the median was 0.21 SMD (interquartile range: 0.13 to 0.45).

Figure 4 displays a modified Bland-Altman diagram comparing point estimates of first trials with point estimates of pooled subsequent trials. Bland-Altman diagrams plot the relationship between each pair of estimates (i.e., first trial vs. pooled subsequent trials). The average of the two measurements, (( effect_first trail_ + effect_pooled trails_ ))/(2) , is plotted on the x-axis; the difference between the measurements, effect_first trail_−effect_pooled trails_, is plotted on the y-axis. In 80 of 100 comparisons, the difference between the point estimate of the first trial and the pooled subsequent trials was smaller than 0.5 SMD (indicated by the dotted lines in Figure 4).

Figure 4 Modified Bland-Altman diagram comparing the point estimates of the first trials with the point estimates of pooled subsequent trials

SMD = standardized mean difference

Figure 4 is a Bland-Altman diagram that plot the relationship between each pair of estimates (i.e., first trial vs. pooled subsequent trials). The average of the two measurements, ((〖effect〗_(first trial)+ 〖effect〗_(pooled trials)) )/2 , is plotted on the x-axis; the difference between the measurements, 〖effect〗_(first trial)-〖effect〗_(pooled trials) , is plotted on the y-axis.Red dots represent that in 80 of 100 comparisons, the difference between the point estimate of the first trial and the pooled subsequent trials was smaller than 0.5 SMD.

To determine whether first trials, on average, favor the experimental intervention, we reordered data for dichotomous outcomes so that a ratio of relative risks of greater than 1 indicated that the first trial presented a more beneficial treatment effect of the experimental arm (either greater benefit or less harm, depending on the outcome) than the pooled subsequent trials. Overall, the pooled estimate of all ratios of relative risks indicated that first trials, on average, did not favor treatment effects of the experimental intervention (ratio of relative risks: 1.03, 95% CI, 0.98 to 1.08).

## Stratified Analyses

In stratified analyses and meta-regression we explored the effects of sample sizes of first and pooled subsequent trials, risk of bias ratings, and magnitude of effects (effects of ≤0.5 SMDs vs. effect >0.5 SMDs) of first trials on the differences in effect estimates between first trials and pooled subsequent trials. Only magnitude of effect estimates of first trials had a statistically significant association (p<0.001) with differences in effect estimates between first trials and subsequent pooled trials. In first trials with treatment effects ≥0.5 SMD, the mean change of estimates of effect between first and pooled subsequent trials was 0.68 SMD (95% CI, .50 to 0.86). Table 2 summarizes Lin's concordance correlations and differences in effect estimates stratified by different characteristics of first trials.

Table 2 Results of stratified analyses based on sample size, risk of bias, and magnitude of effect estimates of first trials

| Lin's Concordance Correlation (rho) of Point Estimates | Pooled Difference in SMDs Between First Trial and Pooled Subsequent Trials (95% CI)
Overall | 0.75 | 0.16 (0.12 to 0.21)
First trials <= 300 participants | 0.77 | 0.25 (0.18 to 0.33)
First trials > 300 participants | 0.83 | 0.14 (0.08 to 0.20)
First trials with low RoB ratings | 0.78 | 0.13 (0.07 to 0.20)
First trials with unclear RoB ratings | 0.74 | 0.30 (0.20 to 0.39)
First trials with high RoB ratings | 0.87 | 0.14 (0.07 to 0.21)
First trials with treatment effects <=0.5 SMDs | 0.87 | 0.04 (0.02 to 0.05)
First trials with treatment effects >0.5 SMDs | 0.87 | 0.68 (0.50 to 0.86)

CI = confidence interval; RoB = risk of bias; SMD = standardized mean difference