# References

1 Gartlehner G, Sommer I, Swinson Evans T, et al. Grades for quality of evidence are associated with distinct likelihoods that treatments effects will remain stable. J Clinical Epidemiology. 2014.
2 Guyatt G, Oxman AD, Akl EA, et al. GRADE guidelines: 1. Introduction-GRADE evidence profiles and summary of findings tables. J Clinical Epidemiology. Apr. 2011;64(4):383-94. Epub: 2011/01/05. [pmid: 21195583].
3 Balshem H, Helfand M, Schunemann HJ, et al. GRADE guidelines: 3. Rating the quality of evidence. J Clinical Epidemiology. 2011;64(4):401-6.
4 Berkman ND, Lohr KN, Ansari M, et al. Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Comparative Effectiveness Reviews. (Prepared by the RTI-UNC Evidence-based Practice Center under Contract No. 290- 2007-10056-I). AHRQ Publication No. 13(14)-EHC130-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2013. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
5 Pereira TV, Horwitz RI, Ioannidis JP. Empirical evaluation of very large treatment effects of medical interventions. JAMA. Oct. 24. 2012;308(16):1676-84. Epub: 2012/10/25. [pmid: 23093165].
6 Trikalinos TA, Churchill R, Ferri M, et al. Effect sizes in cumulative meta-analyses of mental health randomized trials evolved over time. J Clinical Epidemiology. Nov. 2004;57(11):1124-30. [pmid: 15612138].
7 Ioannidis JP, Trikalinos TA. Early extreme contradictory estimates may appear in published research: the Proteus phenomenon in molecular genetics research and randomized trials. J Clinical Epidemiology. Jun. 2005;58(6):543-9. [pmid: 15878467].
8 Dechartres A, Trinquart L, Boutron I, et al. Influence of trial sample size on treatment effect estimates: meta-epidemiological study. BMJ. 2013;346:f2304. [pmid: 23616031].
9 Shojania KG, Sampson M, Ansari MT, et al. Updating Systematic Reviews. Technical Review No. 16. AHRQ Publication No. 07-0087. Rockville, MD. Agency for Healthcare Research and Quality. 2007.
10 Lin LI. A concordance correlation coefficient to evaluate reproducibility. Biometrics. Mar. 1989;45(1):255-68. Epub: 1989/03/01. [pmid: 2720055].
11 Akl Elie A, Gunukula S, Barba M, et al. Parenteral anticoagulation in patients with cancer who have no therapeutic or prophylactic indication for anticoagulation. Cochrane Database of Systematic Reviews. 2011;(4):CD006652.
12 Alejandria Marissa M, Lansang Mary Ann D, Dans Leonila F, et al. Intravenous immunoglobulin for treating sepsis, severe sepsis and septic shock. Cochrane Database of Systematic Reviews. 2013;(9):CD001090. [pmid: 24043371].
13 Amato L, Minozzi S, Vecchi S, et al. Benzodiazepines for alcohol withdrawal. Cochrane Database of Systematic Reviews. 2010;(3):CD005063. [pmid: 20238336].
14 Amato L, Minozzi S, Davoli M, et al. Psychosocial combined with agonist maintenance treatments versus agonist maintenance treatments alone for treatment of opioid dependence. Cochrane Database of Systematic Reviews. 2011;(10):CD004147. [pmid: 21975742].
15 Amato L, Minozzi S, Pani Pier P, et al. Dopamine agonists for the treatment of cocaine dependence. Cochrane Database of Systematic Reviews. 2011;(12):CD003352. [pmid: 22161376].
16 Amato L, Davoli M, Minozzi S, et al. Methadone at tapered doses for the management of opioid withdrawal. Cochrane Database of Systematic Reviews. 2013;(2):CD003409. [pmid: 23450540].
17 Bailey E, Worthington Helen V, van Wijk A, et al. Ibuprofen and/or paracetamol (acetaminophen) for pain relief after surgical removal of lower wisdom teeth. Cochrane Database of Systematic Reviews. 2013;(12):CD004624. [pmid: 24338830].
18 Bauer K, Skoetz N, Monsef I, et al. Comparison of chemotherapy including escalated BEACOPP versus chemotherapy including ABVD for patients with early unfavourable or advanced stage Hodgkin lymphoma. Cochrane Database of Systematic Reviews. 2011;(8):CD007941. [pmid: 21833963].
19 Bird S, Derry S, Moore RA. Zolmitriptan for acute migraine attacks in adults. Cochrane Database of Systematic Reviews. 2014;(5):CD008616. [pmid: 24848613].
20 Boyle Robert J, Elremeli M, Hockenhull J, et al. Venom immunotherapy for preventing allergic reactions to insect stings. Cochrane Database of Systematic Reviews. 2012;(10):CD008838. [pmid: 23076950].
21 Braithwaite T, Nanji Afshan A, Lindsley K, et al. Anti-vascular endothelial growth factor for macular oedema secondary to central retinal vein occlusion. Cochrane Database of Systematic Reviews. 2014;(5):CD007325. [pmid: 24788977].
22 Brito V, Ciapponi A, Kwong J. Factor Xa inhibitors for acute coronary syndromes. Cochrane Database of Systematic Reviews. 2011;(1):CD007038. [pmid: 21249686].
23 Buchleitner Ana M, Martínez-Alonso M, Hernández M, et al. Perioperative glycaemic control for diabetic patients undergoing surgery. Cochrane Database of Systematic Reviews. 2012;(9):CD007315. [pmid: 22972106].
24 Cates Christopher J, Cates Matthew J. Regular treatment with formoterol for chronic asthma: serious adverse events. Cochrane Database of Systematic Reviews. 2012;(4):CD006923. [pmid: 22513944].
25 Cates Christopher J, Welsh Emma J, Rowe Brian H. Holding chambers (spacers) versus nebulisers for beta-agonist treatment of acute asthma. Cochrane Database of Systematic Reviews. 2013;(9):CD000052. [pmid: 24037768].
26 Charoenkwan K, Kietpeerakool C. Retroperitoneal drainage versus no drainage after pelvic lymphadenectomy for the prevention of lymphocyst formation in patients with gynaecological malignancies. Cochrane Database of Systematic Reviews. 2014;(6):CD007387. [pmid: 24894643].
27 Chauhan BF, Ducharme FM. Addition to inhaled corticosteroids of long-acting beta2-agonists versus anti-leukotrienes for chronic asthma. Cochrane Database Syst Rev. 2014:1. CD003137. Epub: 2014/01/25. [pmid: 24459050].
28 Chin KJ, Alakkad H, Adhikary SD, et al. Infraclavicular brachial plexus block for regional anaesthesia of the lower arm. Cochrane Database Syst Rev. 2013:8. CD005487. Epub: 2013/08/30. [pmid: 23986434].
29 Cho Y, Johnson David W, Craig Jonathan C, et al. Biocompatible dialysis fluids for peritoneal dialysis. Cochrane Database of Systematic Reviews. 2014;(3):CD007554. [pmid: 24671928].
30 Chong J, Leung B, Poole P. Phosphodiesterase 4 inhibitors for chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews. 2013;(11):CD002309. [pmid: 24190161].
31 Clarke R, Derry S, Moore RA. Single dose oral etoricoxib for acute postoperative pain in adults. Cochrane Database of Systematic Reviews. 2014;(5):CD004309. [pmid: 24809657].
32 Clifford David M, Fisher Sheila A, Brunskill Susan J, et al. Stem cell treatment for acute myocardial infarction. Cochrane Database of Systematic Reviews. 2012;(2):CD006536. [pmid: 22336818].
33 Costi D, Cyna Allan M, Ahmed S, et al. Effects of sevoflurane versus other general anaesthesia on emergence agitation in children. Cochrane Database of Systematic Reviews. 2014;(9):CD007084. [pmid: 25212274].
34 Eftimov F, Winer John B, Vermeulen M, et al. Intravenous immunoglobulin for chronic inflammatory demyelinating polyradiculoneuropathy. Cochrane Database of Systematic Reviews. 2013;(12):CD001797. [pmid: 24379104].
35 Feagan Brian G, MacDonald John K. Oral 5-aminosalicylic acid for maintenance of remission in ulcerative colitis. Cochrane Database of Systematic Reviews. 2012;(10):CD000544. [pmid: 23076890].
36 Fernandes RM, Bialy LM, Vandermeer B, et al. Glucocorticoids for acute viral bronchiolitis in infants and young children. Cochrane Database Syst Rev. 2013:6. CD004878. Epub: 2013/06/05. [pmid: 23733383].
37 Fransen M, McConnell S, Hernandez-Molina G, et al. Exercise for osteoarthritis of the hip. Cochrane Database of Systematic Reviews. 2014;(4):CD007912. [pmid: 24756895].
38 Fullerton B, Jeitler K, Seitz M, et al. Intensive glucose control versus conventional glucose control for type 1 diabetes mellitus. Cochrane Database of Systematic Reviews. 2014;(2):CD009122. [pmid: 24526393].
39 Gafter-Gvili A, Fraser A, Paul M, et al. Antibiotic prophylaxis for bacterial infections in afebrile neutropenic patients following chemotherapy. Cochrane Database Syst Rev. 2012:1. CD004386. Epub: 2012/01/20. [pmid: 22258955].
40 Gogtay N, Kannan S, Thatte Urmila M, et al. Artemisinin-based combination therapy for treating uncomplicated Plasmodium vivax malaria. Cochrane Database of Systematic Reviews. 2013;(10):CD008492. [pmid: 24163021].
41 Gowing L, Ali R, White JM. Buprenorphine for the management of opioid withdrawal. Cochrane Database Syst Rev. 2009;(3). CD002025. Epub: 2009/07/10. [pmid: 19588330].
42 Griffiths B, Ducharme Francine M. Combined inhaled anticholinergics and short-acting beta2-agonists for initial treatment of acute asthma in children. Cochrane Database of Systematic Reviews. 2013;(8):CD000060. [pmid: 23966133].
43 Gurion R, Belnik-Plitman Y, Gafter-Gvili A, et al. Colony-stimulating factors for prevention and treatment of infectious complications in patients with acute myelogenous leukemia. Cochrane Database of Systematic Reviews. 2012;(6):CD008238. [pmid: 22696376].
44 Hahn D, Cody June D, Hodson Elisabeth M. Frequency of administration of erythropoiesis-stimulating agents for the anaemia of end-stage kidney disease in dialysis patients. Cochrane Database of Systematic Reviews. 2014;(5):CD003895. [pmid: 24872328].
45 Hauser W, Urrutia G, Tort S, et al. Serotonin and noradrenaline reuptake inhibitors (SNRIs) for fibromyalgia syndrome. Cochrane Database Syst Rev. 2013:1. CD010292. Epub: 2013/02/27. [pmid: 23440848].
46 Hayward G, Thompson Matthew J, Perera R, et al. Corticosteroids as standalone or add-on treatment for sore throat. Cochrane Database of Systematic Reviews. 2012;(10):CD008268. [pmid: 23076943].
47 Hemmingsen B, Lund Søren S, Gluud C, et al. Targeting intensive glycaemic control versus targeting conventional glycaemic control for type 2 diabetes mellitus. Cochrane Database of Systematic Reviews. 2013;(11):CD008143. [pmid: 24214280].
48 Hoare Brian J, Wallen Margaret A, Imms C, et al. Botulinum toxin A as an adjunct to treatment in the management of the upper limb in children with spastic cerebral palsy (UPDATE). Cochrane Database of Systematic Reviews. 2010;(1):CD003469. [pmid: 20091546].
49 Hodson Elisabeth M, Ladhani M, Webster Angela C, et al. Antiviral medications for preventing cytomegalovirus disease in solid organ transplant recipients. Cochrane Database of Systematic Reviews. 2013;(2):CD003774. [pmid: 23450543].
50 Holme Ø, Bretthauer M, Fretheim A, et al. Flexible sigmoidoscopy versus faecal occult blood testing for colorectal cancer screening in asymptomatic individuals. Cochrane Database of Systematic Reviews. 2013;(9):CD009259. [pmid: 24085634].
51 Horey D, Kealy M, Davey MA, et al. Interventions for supporting pregnant women's decision-making about mode of birth after a caesarean. Cochrane Database of Systematic Reviews. 2013;(7):CD010041. [pmid: 23897547].
52 Howe Tracey E, Shea B, Dawson Lesley J, et al. Exercise for preventing and treating osteoporosis in postmenopausal women. Cochrane Database of Systematic Reviews. 2011;(7):CD000333. [pmid: 21735380].
53 Hughes Richard AC, Swan Anthony V, van Doorn Pieter A. Intravenous immunoglobulin for Guillain-Barré syndrome. Cochrane Database of Systematic Reviews. 2014;(9):CD002063. [pmid: 25238327].
54 Irving Greg J, Holden J, Yang R, et al. Hepatitis A immunisation in persons not previously exposed to hepatitis A. Cochrane Database of Systematic Reviews. 2012;(7):CD009051. [pmid: 22786522].
55 Itchaki G, Gafter-Gvili A, Lahav M, et al. Anthracycline-containing regimens for treatment of follicular lymphoma in adults. Cochrane Database of Systematic Reviews. 2013;(7):CD008909. [pmid: 23832787].
56 Karner C, Chong J, Poole P. Tiotropium versus placebo for chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews. 2014;(7):CD009285. [pmid: 25046211].
57 Katalinic Owen M, Harvey Lisa A, Herbert Robert D, et al. Stretch for the treatment and prevention of contractures. Cochrane Database of Systematic Reviews. 2010;(9):CD007455. [pmid: 20824861].
58 Kew Kayleigh M, Karner C, Mindus Stephanie M, et al. Combination formoterol and budesonide as maintenance and reliever therapy versus combination inhaler maintenance for chronic asthma in adults and children. Cochrane Database of Systematic Reviews. 2013;(12):CD009019. [pmid: 24343671].
59 Kew Kayleigh M, Seniukovich A. Inhaled steroids and risk of pneumonia for chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews. 2014;(3):CD010115. [pmid: 24615270].
60 Koretz Ronald L, Pleguezuelo M, Arvaniti V, et al. Interferon for interferon nonresponding and relapsing patients with chronic hepatitis C. Cochrane Database of Systematic Reviews. 2013;(1):CD003617. [pmid: 23440791].
61 Kramer Christine V, Zhang F, Sinclair D, et al. Drugs for treating urinary schistosomiasis. Cochrane Database of Systematic Reviews. 2014;(8):CD000053. [pmid: 25099517].
62 Kruis Annemarije L, Smidt N, Assendelft Willem JJ, et al. Integrated disease management interventions for patients with chronic obstructive pulmonary disease. Cochrane Database of Systematic Reviews. 2013;(10):CD009437. [pmid: 24108523].
63 Kumar P, Chawla D, Deorari A. Light-emitting diode phototherapy for unconjugated hyperbilirubinaemia in neonates. Cochrane Database of Systematic Reviews. 2011;(12):CD007969. [pmid: 22161417].
64 La Mantia L, Vacchi L, Di Pietrantonj C, et al. Interferon beta for secondary progressive multiple sclerosis. Cochrane Database of Systematic Reviews. 2012;(1):CD005181. [pmid: 22258960].
65 Lai Nai M, Chaiyakunapruk N, Lai Nai A, et al. Catheter impregnation, coating or bonding for reducing central venous catheter-related infections in adults. Cochrane Database of Systematic Reviews. 2013;(6):CD007878. [pmid: 23740696].
66 Law S, Derry S, Moore RA. Sumatriptan plus naproxen for acute migraine attacks in adults. Cochrane Database of Systematic Reviews. 2013;(10):CD008541. [pmid: 24142431].
67 Lazzerini M, Ronfani L. Oral zinc for treating diarrhoea in children. Cochrane Database of Systematic Reviews. 2013;(1):CD005436. [pmid: 23440801].
68 Lemiengre MB, van Driel ML, Merenstein D, et al. Antibiotics for clinically diagnosed acute rhinosinusitis in adults. Cochrane Database Syst Rev. 2012:10. CD006089. Epub: 2012/10/19. [pmid: 23076918].
69 Lewis Sharon R, Nicholson A, Cardwell Mary E, et al. Nonsteroidal anti-inflammatory drugs and perioperative bleeding in paediatric tonsillectomy. Cochrane Database of Systematic Reviews. 2013;(7):CD003591. [pmid: 23881651].
70 Li Edmond CK, Heran Balraj S, Wright James M. Angiotensin converting enzyme (ACE) inhibitors versus angiotensin receptor blockers for primary hypertension. Cochrane Database of Systematic Reviews. 2014;(8):CD009096. [pmid: 25148386].
71 Liakopoulos Oliver J, Kuhn Elmar W, Slottosch I, et al. Preoperative statin therapy for patients undergoing cardiac surgery. Cochrane Database of Systematic Reviews. 2012;(4):CD008493. [pmid: 22513959].
72 Lopez-Olivo Maria A, Siddhanamatha Harish R, Shea B, et al. Methotrexate for treating rheumatoid arthritis. Cochrane Database of Systematic Reviews. 2014;(6):CD000957. [pmid: 24916606].
73 Main C, Knight B, Moxham T, et al. Hormone therapy for preventing cardiovascular disease in post-menopausal women. Cochrane Database of Systematic Reviews. 2013;(4):CD002229. [pmid: 23633307].
74 Manheimer E, Cheng K, Linde K, et al. Acupuncture for peripheral joint osteoarthritis. Cochrane Database of Systematic Reviews. 2010;(1):CD001977. [pmid: 20091527].
75 Massel David R, Little Stephen H. Antiplatelet and anticoagulation for patients with prosthetic heart valves. Cochrane Database of Systematic Reviews. 2013;(7):CD003464. [pmid: 23839768].
76 Middeldorp S, Prins Martin H, Hutten Barbara A. Duration of treatment with vitamin K antagonists in symptomatic venous thromboembolism. Cochrane Database of Systematic Reviews. 2014;(8):CD001367. [pmid: 25092359].
77 Moja L, Tagliabue L, Balduzzi S, et al. Trastuzumab containing regimens for early breast cancer. Cochrane Database of Systematic Reviews. 2012;(4):CD006243. [pmid: 22513938].
78 Mössler K, Chen X, Heldal Tor O, et al. Music therapy for people with schizophrenia and schizophrenia-like disorders. Cochrane Database of Systematic Reviews. 2011;(12):CD004025. [pmid: 22161383].
79 Musini Vijaya M, Nazer M, Bassett K, et al. Blood pressure-lowering efficacy of monotherapy with thiazide diuretics for primary hypertension. Cochrane Database of Systematic Reviews. 2014;(5):CD003824. [pmid: 24869750].
80 Musini Vijaya M, Tejani Aaron M, Bassett K, et al. Pharmacotherapy for hypertension in the elderly. Cochrane Database of Systematic Reviews. 2009;(4):CD000028. [pmid: 19821263].
81 Nannini LJ, Poole P, Milan SJ, et al. Combined corticosteroid and long-acting beta2-agonist in one inhaler versus inhaled corticosteroids alone for chronic obstructive pulmonary disease. Cochrane Database Syst Rev. 2013:8. CD006826. Epub: 2013/08/31. [pmid: 23990350].
82 Nelson Richard L, Chattopadhyay A, Brooks W, et al. Operative procedures for fissure in ano. Cochrane Database of Systematic Reviews. 2011;(11):CD002199. [pmid: 22071803].
83 Nelson Richard L, Thomas K, Morgan J, et al. Non surgical therapy for anal fissure. Cochrane Database of Systematic Reviews. 2012;(2):CD003431. [pmid: 22336789].
84 Nelson Richard L, Gladman E, Barbateskovic M. Antimicrobial prophylaxis for colorectal surgery. Cochrane Database of Systematic Reviews. 2014;(5):CD001181. [pmid: 24817514].
85 Nuesch E, Rutjes AW, Husni E, et al. Oral or transdermal opioids for osteoarthritis of the knee or hip. Cochrane Database Syst Rev. 2009;(4). CD003115. Epub: 2009/10/13. [pmid: 19821302].
86 Nussbaum Abraham M, Stroup TS. Paliperidone palmitate for schizophrenia. Cochrane Database of Systematic Reviews. 2012;(6):CD008296. [pmid: 22696377].
87 Pandian Z, Marjoribanks J, Ozturk O, et al. Number of embryos for transfer following in vitro fertilisation or intracytoplasmic sperm injection. Cochrane Database of Systematic Reviews. 2013;(7):CD003416. [pmid: 23897513].
88 Pani Pier P, Trogu E, Vecchi S, et al. Antidepressants for cocaine dependence and problematic cocaine use. Cochrane Database of Systematic Reviews. 2011;(12):CD002950. [pmid: 22161371].
89 Paul M, Dickstein Y, Schlesinger A, et al. Beta-lactam versus beta-lactam-aminoglycoside combination therapy in cancer patients with neutropenia. Cochrane Database of Systematic Reviews. 2013;(6):CD003038. [pmid: 23813455].
90 Perez Marco I, Musini Vijaya M, Wright James M. Effect of early treatment with anti-hypertensive drugs on short and long-term mortality in patients with an acute cardiovascular event. Cochrane Database of Systematic Reviews. 2009;(4):CD006743. [pmid: 19821384].
91 Rajaram Sujanthy S, Desai Nayan K, Kalra A, et al. Pulmonary artery catheters for adult patients in intensive care. Cochrane Database of Systematic Reviews. 2013;(2):CD003408. [pmid: 23450539].
92 Rehman H, Bezerra CC, Bruschini H, et al. Traditional suburethral sling operations for urinary incontinence in women. Cochrane Database Syst Rev. 2011;(1). CD001754. Epub: 2011/01/21. [pmid: 21249648].
93 Richards J, Hillsdon M, Thorogood M, et al. Face-to-face interventions for promoting physical activity. Cochrane Database of Systematic Reviews. 2013;(9):CD010392. [pmid: 24085592].
94 Rubinstein Sidney M, van Middelkoop M, Assendelft Willem JJ, et al. Spinal manipulative therapy for chronic low-back pain. Cochrane Database of Systematic Reviews. 2011;(2):CD008112. [pmid: 21328304].
95 Santa Cruz R, Rojas Juan I, Nervi R, et al. High versus low positive end-expiratory pressure (PEEP) levels for mechanically ventilated adult patients with acute lung injury and acute respiratory distress syndrome. Cochrane Database of Systematic Reviews. 2013;(6):CD009098. [pmid: 23740697].
96 Shepperd S, Wee B, Straus Sharon E. Hospital at home: home-based end of life care. Cochrane Database of Systematic Reviews. 2011;(7):CD009231. [pmid: 21735440].
97 Sinclair D, Abba K, Zaman K, et al. Oral vaccines for preventing cholera. Cochrane Database of Systematic Reviews. 2011;(3):CD008603. [pmid: 21412922].
98 Soares-Weiser K, MacLehose H, Bergman H, et al. Vaccines for preventing rotavirus diarrhoea: vaccines in use. Cochrane Database of Systematic Reviews. 2012;(11):CD008521.
99 Solomon Sharon D, Lindsley K, Vedula Satyanarayana S, et al. Anti-vascular endothelial growth factor for neovascular age-related macular degeneration. Cochrane Database of Systematic Reviews. 2014;(8):CD005139. [pmid: 25170575].
100 Spinks A, Glasziou Paul P, Del Mar Chris B. Antibiotics for sore throat. Cochrane Database of Systematic Reviews. 2013;(11):CD000023. [pmid: 24190439].
101 Swinnen Sanne G, Simon Airin CR, Holleman F, et al. Insulin detemir versus insulin glargine for type 2 diabetes mellitus. Cochrane Database of Systematic Reviews. 2011;(7):CD006383. [pmid: 21735405].
102 Tacklind J, MacDonald R, Rutks I, et al. Serenoa repens for benign prostatic hyperplasia. Cochrane Database of Systematic Reviews. 2012;(12):CD001423. [pmid: 23235581].
103 Tangsiriwatthana T, Sangkomkamhang Ussanee S, Lumbiganon P, et al. Paracervical local anaesthesia for cervical dilatation and uterine intervention. Cochrane Database of Systematic Reviews. 2013;(9):CD005056. [pmid: 24085642].
104 Thomas J, Fairclough A, Kavanagh J, et al. Vaginal prostaglandin (PGE2 and PGF2a) for induction of labour at term. Cochrane Database of Systematic Reviews. 2014;(6):CD003101. [pmid: 24941907].
105 Torrego A, Solà I, Munoz Ana M, et al. Bronchial thermoplasty for moderate or severe persistent asthma in adults. Cochrane Database of Systematic Reviews. 2014;(3):CD009910. [pmid: 24585221].
106 Venekamp Roderick P, Sanders S, Glasziou Paul P, et al. Antibiotics for acute otitis media in children. Cochrane Database of Systematic Reviews. 2013;(1):CD000219. [pmid: 23440776].
107 Webster J, Osborne S, Rickard Claire M, et al. Clinically-indicated replacement versus routine replacement of peripheral venous catheters. Cochrane Database of Systematic Reviews. 2013;(4):CD007798. [pmid: 23633346].
108 Wilhelmus Kirk R. Antiviral treatment and other therapeutic interventions for herpes simplex virus epithelial keratitis. Cochrane Database of Systematic Reviews. 2010;(12):CD002898. [pmid: 21154352].
109 Yeoh B, Woolfenden S, Lanphear B, et al. Household interventions for preventing domestic lead exposure in children. Cochrane Database of Systematic Reviews. 2012;(4):CD006047. [pmid: 22513934].
110 Yuan Y, Zeng X, Hu Y, et al. Omentoplasty for oesophagogastrostomy after oesophagectomy. Cochrane Database of Systematic Reviews. 2014;(10):CD008446. [pmid: 25274134].
111 Cohen J. Statistical Power Analysis for the Behavioral Sciences. 2nd Ed. Hillsdale, NJ. Lawrence Erlbaum Associates. 1988.
112 Norman GR, Sloan JA, Wyrwich KW. The truly remarkable universality of half a standard deviation: confirmation through another look. Expert Rev Pharmacoecon Outcomes Res. Oct. 2004;4(5):581-5. [pmid: 19807551].
113 Trikalinos TA, Ntzani EE, Contopoulos-Ioannidis DG, et al. Establishment of genetic associations for complex diseases is independent of early study findings. Eur J Hum Genet. Sep. 2004;12(9):762-9. Epub: 2004/06/24. [pmid: 15213707].
114 Mustafa RA, Santesso N, Brozek J, et al. The GRADE approach is reproducible in assessing the quality of evidence of quantitative evidence syntheses. J Clinical Epidemiology. Jul. 2013;66(7):736-42 e5. [pmid: 23623694].