# Methods

To address our objective, we used a meta-epidemiological approach based on large, systematically appraised bodies of evidence that Cochrane authors had graded as high QOE. We used effect estimates of high QOE studies as reference points because a grade of high QOE implies that investigators were very confident that the effect estimate is close to the truth and that new studies are unlikely to change conclusions. The basic assumption for our study was that these bodies of evidence had been graded correctly and can serve as reference points to evaluate whether the first published trial of each body of evidence showed concordant or discordant effect estimates compared with the remaining body of evidence.

## Empirical Data

We systematically searched the Cochrane Library from 2010 to July 2014 to find Cochrane reports that presented the QOE in “summary-of-findings” tables. According to the Methodological Expectations of Cochrane Intervention Reviews (MECIR), summary-of-findings tables are highly desirable but not mandatory. Consequently, not all Cochrane reviews present them. We used “quality of evidence” OR “summary of findings” as search terms. Out of 1325 records, 1311 presented summary of findings tables. Of those, 293 reported at least one high QOE rating. From these, we randomly selected 100 reports that had to fulfill the following criteria: (1) include a body of evidence comprising more than three RCTs on therapeutic interventions two Cochrane authors graded independently as high QOE; (2) present meta-analytic outcomes authors reported as relative risks or odds ratios for binary outcomes, and as weighted mean differences or standardized mean differences (SMDs) for continuous outcomes; and (3) provide data to reproduce the meta-analyses.

If a review reported more than one high-QOE outcome, we randomly selected one outcome per review.

## Assessing Concordance in Effect Estimates

To assess the concordance or discordance of effect estimates between the first published trial of a body of evidence (termed “first trial”) and the pooled effect estimate of all trials that were published subsequently (termed “pooled subsequent trials”), we employed qualitative and quantitative methods. For all 100 bodies of evidence, we calculated the effect estimate of the first trial and the pooled estimate of the subsequent trials. For continuous outcomes we used SMDs (Cohen's d) as effect measures; for dichotomous outcomes we calculated relative risks.

To compare two independent samples of data, we did not include the first trial in the meta-analysis of the subsequent trials. For all meta-analyses we used DerSimonian-Laird random effects models.

Figure 1 illustrates the approach. The first row in the forest plot represents the first trial published (trial 1). The subsequent rows present the trials that were published later, following the first trial (trials 2-9). The pooled estimate in Figure 1 is the meta-analysis of trials 2 through 9 (the pooled subsequent trials).

Figure 1 Illustration of assessing the concordance in effect estimates between a first trial and the pooled subsequent trials

Figure 1. Is a forest plot that illustrates the meta-analyses using DerSimonian-Laird random effects models. The first row in the forest plot represents the first trial published (trial 1) represented by a red square. The subsequent rows present the trials that were published later, following the first trial (trials 2-9) represented by green squares. The pooled estimate in Figure 1 is the meta-analysis of trials 2 through 9 (the pooled subsequent trials).

## Qualitative Assessment of Concordance

We determined qualitative concordance based on a two-tiered approach incorporating changes in statistical significance and magnitude of effect. This approach was originally proposed to detect signals for updating systematic reviews;9 we modified it for our purposes. We deemed the first trial and the pooled subsequent trials as concordant when:

1. Statistical significance did not change, and
2. The magnitude of treatment effects remained similar.

The first criterion captures whether a result that was statistically significant in the first trial was not statistically significant in the pooled subsequent trials or vice versa—a previously nonsignificant result has become statistically significant. To avoid counting trivial or ‘borderline’ changes in statistical significance, we required that at least one of the two results have a p-value outside the range of 0.04 to 0.06. In other words, we did not consider cases in which a p-value changed statistical significance within this range (e.g., a change from p=0.041 to p=0.059 did not count as a change in statistical significance, nor did the converse change from p=0.059 to p=0.041).

The second criterion assessed whether the magnitude of change of the effect estimate between first trial and pooled subsequent trials was smaller than a predefined threshold. We employed three different thresholds to determine the similarity of treatment effects.

1. A relative risk increase or reduction of less than 25 percentage points for dichotomous outcomes and less than 0.20 SMDs for continuous outcomes;
2. A relative risk increase or reduction of less than 50 percentage points for dichotomous outcomes and less than 0.5 SMDs for continuous outcomes;
3. A staggered approach based on the magnitude of treatment effect in the first trial and the type of outcome
  a. For first trials with regular treatment effects (relative risk 0.5 to 2.00, or SMD <0.8) a change in relative risk increase/reduction of less than 25 percentage points or less than 0.20 SMD
  b. For first trials with large treatment effects (relative risk 0.5 and >2.00, or SMD>0.8), a change in relative risk increase/reduction of less than 50 percentage points or less than 0.5 SMD.
  c. For outcomes that can be considered extremely patient-relevant (e.g., mortality, stroke, myocardial infarction) a change in relative risk of less than 10 percentage points.

To determine concordance between first trials and pooled subsequent trials, we programmed and tested a Microsoft Excel spreadsheet that employed the above criteria.

## Quantitative Assessment of Concordance

To assess quantitatively the concordance between effect estimates of first trials and pooled effects of subsequent trials, we employed three strategies (an explanation of the equations is provided in the Equations section for accessibility purposes).

First, to test for concordance, we used Lin's concordance correlation coefficient.10 To be able to use a common metric for all studies, we converted dichotomous outcomes to SMDs using the following formula: d = log OddsRatio ∗ (sqrt(3))/(π)

Lin's concordance correlation determines how closely related two variables are in a linear fashion and how they correspond to each other. A value of +1 indicates perfect concordance, a value of -1 reflects perfect discordance, and a value of 0 denotes the absence of either concordance or discordance. We determined the concordance for point estimates and z-scores of first trials and pooled subsequent trials.

Second, to test for statistically significant differences between effect estimates, we calculated z-scores comparing the effect estimates of the first and the pooled subsequent trials: z = (effect_first trail_ − effect_pooled trails_)/(sqrt(variance_first trail_ + variance_pooled trails_))

Third, to determine differences in magnitudes of effect estimates between first and pooled subsequent trials, we calculated differences in SMDs (Cohen's d) for all comparisons and ratios of relative risks for dichotomous outcomes. We used DerSimonian-Laird random-effects meta-analyses to calculate summary differences in magnitudes of effects.

To determine the influence of risk of bias, sample sizes of first and pooled subsequent trial, and the magnitude of effect estimates of the first trial on results, we employed meta-regression analyses.

We conducted statistical analyses using Stata IC 13 (Stata Corporation, TX, USA), Comprehensive Meta-Analysis V2 (Biostat Inc, Englewood, NJ, USA), and Microsoft Excel 2010 (Microsoft Corporation, Redmond, WA, USA).