# Introduction

GRADE (Grading of Recommendations Assessment, Development and Evaluation) has become a widely adopted approach for conveying the uncertainty associated with findings and conclusions present in systematic reviews.1 GRADE is thought to reflect, explicitly and transparently, the confidence that researchers have in an available body of evidence.2 Its conceptual framework uses information about risk of bias, imprecision, inconsistency, indirectness, and publication bias to communicate the confidence that systematic reviewers have in estimates of treatment effects; GRADE calls this “quality of evidence” (QOE).3 In the context of systematic reviews, GRADE defines QOE as the extent of the confidence that the estimates of an effect are correct. A grade of high QOE, for example, means that reviewers are confident that the effect estimate is close to the true effect and that new studies will not change the conclusions.

Assessing bodies of evidence that are limited to single studies is a particular challenge for systematic reviewers for two reasons: (1) consistency of results with other studies cannot. be determined, and (2) whether the first study published is also the first study conducted (or whether the first study published is just the most favorable study conducted) is usually unclear. Both GRADE guidance and related guidance for the U.S. Agency for Healthcare Research and Quality (AHRQ) Evidence-based Practice Center program recommend using the same approach for single- and multiple-study bodies of evidence.3,4 Nevertheless, because reviewers cannot be certain that a single study, no matter how large, presents a definitive picture of the benefits and harms of a given treatment,4 in practice they often tend to grade single-study bodies of evidence as low or very low.

A QOE of low or very low reflects a general lack of confidence in effect estimates. Whether effect estimates substantially change as a body of evidence advances from a single trial to a reliable body of evidence that is rated as high QOE, has not been examined yet. Several previous studies examined how research evidence evolves over time.5-7 Results indicate that direction and magnitude of effects change, particularly if first studies report very large treatment effects.5-8 None of these studies, however, compared the estimates of effects of first studies to reference points that other researchers determined to be reliable and of high certainty with respect to the correctness of effect estimates.

The objective of our methods project was to assess empirically whether first trials of a diverse sample of medical interventions rendered substantially different treatment effect estimates than reliable, high-quality bodies of evidence.