# Peer Reviewers

Prior to publication of the white paper, we sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential non-financial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential non-financial conflicts of interest identified.

The list of Peer Reviewers follows:

- Nancy Berkman, Ph.D.
  Senior Research Analyst
  RTI International
  Research Triangle Park, NC
- Philippe Ravaud, M.D.
  Senior Lecturer of Epidemiology
  Columbia University's Mailman School of Public Health
  New York, NY
  Professor of Epidemiology, Paris Descartes University
  Director, the French Cochrane Center
  Paris, France
- Paul Shekelle, M.D., Ph.D.
  Director, Southern California Evidence-Based Practice Center, RAND Corporation
  Santa Monica, CA
- Jonathan Treadwell, Ph.D.
  Associate Director, ECRI Institute Evidence-based Practice Center
  Plymouth Meeting, PA
- Thomas Trikalinos, M.D., Ph.D.
  Associate Professor of Health Services, Policy and Practice
  Director of Evidence-Based Medicine, Brown University
  Providence, RI
- Alex Ellis, Ph.D. Candidate
  Brown University
  Providence, RI