# Equations

Equation 1. | Lin's concordance correlation | Equation 1 is a linear equation for converting dichotomous outcomes to SMDs. The equation is as follows:; d=log^f()^〖OddsRatio* √3/π Equation 1 is a linear equation for converting dichotomous outcomes to SMDs. The equation is as follows: d=logf()〖OddsRatio* √3/π
Equation 2. | Z-scores | Equation 2 is a linear type of equation for calculating z scores. The equation is as follows:; z=(〖effect〗_(first trial)-〖effect〗_(pooled trials))/(√(〖〖variance〗_(first trial )〗^+〖〖variance〗_(pooled trials )〗^ ) ) Equation 2 is a linear type of equation for calculating z scores. The equation is as follows: z=(〖effect〗_(first trial)-〖effect〗_(pooled trials))/(√(〖〖variance〗_(first trial )〗^+〖〖variance〗_(pooled trials )〗^ ) )
Equation 3. | Bland-Altman Diagram | Equation 3 is a graphical type of equation for plotting the relationship between a pair of estimates. The equation is as follows:; ((〖effect〗_(first trial)+ 〖effect〗_(pooled trials)) )/2 Equation 3 is a graphical type of equation for plotting the relationship between a pair of estimates. The equation is as follows: ((〖effect〗_(first trial)+ 〖effect〗_(pooled trials)) )/2
Equation 4. | Bland-Altman Diagram | Equation 4 is a graphical type of equation for plotting the relationship between a pair of estimates. The equation is as follows:; 〖effect〗_(first trial)-〖effect〗_(pooled trials) Equation 4 is a graphical type of equation for plotting the relationship between a pair of estimates. The equation is as follows: 〖effect〗_(first trial)-〖effect〗_(pooled trials)