# Discussion

To our knowledge, our study was the first attempt to use high-quality bodies of evidence as reference points to assess the magnitude of changes of effect estimates as bodies of evidence advance from a first trial to a reliable body of evidence graded as high QOE. The premise of our study was the GRADE approach and its definitions. GRADE links QOE grades to the degree of confidence that estimates are close to the true effect (and thus will remain stable as new evidence accrues). This concept can be criticized from a philosophical perspective because quantifiable entities (grades of QOE) are linked to an abstract concept (the truth) that can never be verified. Nevertheless, we purposely took GRADE definitions at face value. GRADE is used by more than 70 international organizations; most decisionmakers conceivably accept and rely on GRADE assessments and their current definitions.

Results of our meta-epidemiological research indicate that first trials both over- and under-estimate the true effects; we could find no discernable pattern. The average magnitude of difference, however, is relatively small. In 80 percent of comparisons the difference in effect estimates was smaller than 0.5 SMD, which is often viewed as a moderate treatment effect.111,112 Depending on how we defined concordance of effects, effect estimates of first trials were concordant with pooled subsequent studies in at least 33 percent but up to 50 percent of these comparisons. The largest change in effect estimates occurred when first trials reported large treatment effects.

Our findings empirically confirm current GRADE and AHRQ guidance that systematic reviewers should not grade single-study bodies of evidence as very low (or insufficient for AHRQ EPCs) simply by default. Risk of bias, precision and magnitude of effect estimates, publication bias, or issues of directness vary substantially across single-study bodies of evidence; reviewers should take these factors into account to achieve a nuanced QOE assessment. Reviewers can, of course, still assign a grade of very low when warranted by problems such as imprecision, indirectness of evidence, or other problems such as publication bias.

A highly cited article by Pereira et al.5 compared very large treatment effects (i.e., treatment effects with an odds ratio ≥5) of first trials with effect estimates of subsequent trials.5 Those authors concluded that most large treatment effects become much smaller as new studies emerge. These findings are compatible with ours, although a substantial decrease in very large treatment effects of first trials as new evidence emerges is probably attributable mostly to regression to the mean. Trikalinos et al. and Dechartres et al. also report changes in treatment effects without a discernible pattern as evidence evolves.6,8 Other studies focused mainly on genetic associations, which are difficult to compare with clinical interventions.7,113 The main difference between our research and other studies is that our investigation focused on high-quality bodies of evidence as reference points with which we compared the effect estimates of first trials. Other studies included any meta-analysis, regardless of QOE assessments.7,8,113

Our study has several limitations. First, the size of our sample was limited. We included 100 bodies of evidence that had been graded as high QOE. Because of the consistency of our findings across a broad array of clinical topics, however, we believe that the overall conclusion would not change substantially with a larger sample of bodies of evidence.

Second, how representative our sample is remains unclear. Because we wanted to use a reference standard for which researchers had high confidence that effect estimates are correct (close to the true effect), we focused on high QOE evidence. A remaining question is whether bodies of evidence that will never progress to high QOE would have the same degree of concordance between first trials and subsequent trials as our sample.

Third, we relied on QOE grades of Cochrane authors. Because author groups differed across these systematic reviews, some heterogeneity in approaches regarding QOE grades is likely. Studies have shown that the inter-rater reliability of QOE grades is limited.4,114 Nevertheless, such heterogeneity reflects a real-world situation because most guideline developers or other decisionmakers that use Cochrane reports to support decisions would not reassess QOE. In addition, Cochrane reports go through rigorous international peer review, and the methodological quality usual is high.

Finally, how to determine the effect of publication bias on results of our study is unclear. Realistically, publication bias could play a role in any systematic review. We were not able to assess whether a first trial in a meta-analysis of the Cochrane report was actually the first trial conducted. First trials without statistically significant results may have never been published. Also, the body of subsequent investigations may not represent that totality of evidence conducted for a given comparison. How these biases affect the difference in magnitudes of effect estimates between first and pooled subsequent trials is unclear.