# References

1 Atkins D, Siegel J, Slutsky J. Making policy when the evidence is in dispute. Health Affairs (Millwood). Jan-Feb. 2005;24(1):102-13. Epub: 2005/01/14. [pmid: 15647220].
2 Schunemann HJ, Hill SR, Kakad M, et al. Transparent development of the WHO rapid advice guidelines. PLoS Med. May. 2007;4(5):e119. [pmid: 17535099].
3 Qaseem A, Forland F, Macbeth F, et al. Guidelines international network: toward international standards for clinical practice guidelines. Ann Intern Med. Apr. 3. 2012;156(7):525-31. Epub: 2012/04/05. [pmid: 22473437].
4 Berkman ND, Lohr KN, Ansari M, et al. Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Comparative Effectiveness Reviews. (Prepared by the RTI-UNC Evidence-based Practice Center under Contract No. 290-2007-10056-I). AHRQ Publication No. 13(14)-EHC130-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2013. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
5 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions––Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
6 Gartlehner G, Sommer I, Evans TS, et al. Grades for quality of evidence were associated with distinct likelihoods that treatment effects will remain stable. J Clin Epidemiol. May. 2015;68(5):489-97. [pmid: 25484316].
7 Cronbach LJ, Meehl PE. Construct validity in psychological tests. Psychological Bulletin. Jul. 1955;52(4):281-302. [pmid: 13245896].
8 Borenstein M, Hedges LV, Higgins JPT, et al. Introduction to Meta-Analysis. John Wiley & Sons Ltd. 2009.
9 Amato L, Minozzi S, Vecchi S, et al. Benzodiazepines for alcohol withdrawal. Cochrane Database Syst Rev. 2010;(3). CD005063. [pmid: 20238336].
10 Amato L, Minozzi S, Davoli M, et al. Psychosocial combined with agonist maintenance treatments versus agonist maintenance treatments alone for treatment of opioid dependence. Cochrane Database Syst Rev. 2011;(10). CD004147. Epub: 2011/10/07. [pmid: 21975742].
11 Amato L, Davoli M, Minozzi S, et al. Methadone at tapered doses for the management of opioid withdrawal. Cochrane Database Syst Rev. 2013;2. CD003409. Epub: 2013/03/02. [pmid: 23450540].
12 Buchleitner AM, Martinez-Alonso M, Hernandez M, et al. Perioperative glycaemic control for diabetic patients undergoing surgery. Cochrane Database Syst Rev. 2012;9(9). CD007315. [pmid: 22972106].
13 Chauhan BF, Ducharme FM. Addition to inhaled corticosteroids of long-acting beta2-agonists versus anti-leukotrienes for chronic asthma. Cochrane Database Syst Rev. 2014;1. CD003137. Epub: 2014/01/25. [pmid: 24459050].
14 Chin KJ, Alakkad H, Adhikary SD, et al. Infraclavicular brachial plexus block for regional anaesthesia of the lower arm. Cochrane Database Syst Rev. 2013;8. CD005487. Epub: 2013/08/30. [pmid: 23986434].
15 Chong J, Leung B, Poole P. Phosphodiesterase 4 inhibitors for chronic obstructive pulmonary disease. Cochrane Database Syst Rev. 2013;11(11). CD002309. [pmid: 24190161].
16 Clifford DM, Fisher SA, Brunskill SJ, et al. Stem cell treatment for acute myocardial infarction. Cochrane Database Syst Rev. 2012;2(2). CD006536. [pmid: 22336818].
17 Feagan BG, Macdonald JK. Oral 5-aminosalicylic acid for maintenance of remission in ulcerative colitis. Cochrane Database Syst Rev. 2012;10(10). CD000544. [pmid: 23076890].
18 Fernandes RM, Bialy LM, Vandermeer B, et al. Glucocorticoids for acute viral bronchiolitis in infants and young children. Cochrane Database Syst Rev. 2013;6. CD004878. Epub: 2013/06/05. [pmid: 23733383].
19 Gafter-Gvili A, Fraser A, Paul M, et al. Antibiotic prophylaxis for bacterial infections in afebrile neutropenic patients following chemotherapy. Cochrane Database Syst Rev. 2012;1. CD004386. Epub: 2012/01/20. [pmid: 22258955].
20 Gowing L, Ali R, White JM. Buprenorphine for the management of opioid withdrawal. Cochrane Database Syst Rev. 2009;(3). CD002025. Epub: 2009/07/10. [pmid: 19588330].
21 Griffiths B, Ducharme FM. Combined inhaled anticholinergics and short-acting beta2-agonists for initial treatment of acute asthma in children. Cochrane Database Syst Rev. 2013;8(8). CD000060. [pmid: 23966133].
22 Gurion R, Belnik-Plitman Y, Gafter-Gvili A, et al. Colony-stimulating factors for prevention and treatment of infectious complications in patients with acute myelogenous leukemia. Cochrane Database Syst Rev. 2012;6(6). CD008238. [pmid: 22696376].
23 Hauser W, Urrutia G, Tort S, et al. Serotonin and noradrenaline reuptake inhibitors (SNRIs) for fibromyalgia syndrome. Cochrane Database Syst Rev. 2013;1. CD010292. Epub: 2013/02/27. [pmid: 23440848].
24 Hemmingsen B, Lund SS, Gluud C, et al. Targeting intensive glycaemic control versus targeting conventional glycaemic control for type 2 diabetes mellitus. Cochrane Database Syst Rev. 2013;11(11). CD008143. [pmid: 24214280].
25 Hodson EM, Ladhani M, Webster AC, et al. Antiviral medications for preventing cytomegalovirus disease in solid organ transplant recipients. Cochrane Database Syst Rev. 2013;2(2). CD003774. [pmid: 23450543].
26 Howe TE, Shea B, Dawson LJ, et al. Exercise for preventing and treating osteoporosis in postmenopausal women. Cochrane Database Syst Rev. 2011;(7). CD000333. [pmid: 21735380].
27 Katalinic OM, Harvey LA, Herbert RD, et al. Stretch for the treatment and prevention of contractures. Cochrane Database Syst Rev. 2010;(9). CD007455. [pmid: 20824861].
28 Lai NM, Chaiyakunapruk N, Lai NA, et al. Catheter impregnation, coating or bonding for reducing central venous catheter-related infections in adults. Cochrane Database Syst Rev. 2013;6(6). CD007878. [pmid: 23740696].
29 Law S, Derry S, Moore RA. Sumatriptan plus naproxen for acute migraine attacks in adults. Cochrane Database Syst Rev. 2013;10(10). CD008541. [pmid: 24142431].
30 Lemiengre MB, van Driel ML, Merenstein D, et al. Antibiotics for clinically diagnosed acute rhinosinusitis in adults. Cochrane Database Syst Rev. 2012;10. CD006089. Epub: 2012/10/19. [pmid: 23076918].
31 Lewis SR, Nicholson A, Cardwell ME, et al. Nonsteroidal anti-inflammatory drugs and perioperative bleeding in paediatric tonsillectomy. Cochrane Database Syst Rev. 2013;7(7). CD003591. [pmid: 23881651].
32 Liakopoulos OJ, Kuhn EW, Slottosch I, et al. Preoperative statin therapy for patients undergoing cardiac surgery. Cochrane Database Syst Rev. 2012;4(4). CD008493. [pmid: 22513959].
33 Main C, Knight B, Moxham T, et al. Hormone therapy for preventing cardiovascular disease in post-menopausal women. Cochrane Database Syst Rev. 2013;4(4). CD002229. [pmid: 23633307].
34 Moja L, Tagliabue L, Balduzzi S, et al. Trastuzumab containing regimens for early breast cancer. Cochrane Database of Systematic Reviews. 2012;(4). CD006243.
35 Musini VM, Tejani AM, Bassett K, et al. Pharmacotherapy for hypertension in the elderly. Cochrane Database Syst Rev. 2009;(4). CD000028. [pmid: 19821263].
36 Nannini LJ, Poole P, Milan SJ, et al. Combined corticosteroid and long-acting beta2-agonist in one inhaler versus inhaled corticosteroids alone for chronic obstructive pulmonary disease. Cochrane Database Syst Rev. 2013;8. CD006826. Epub: 2013/08/31. [pmid: 23990350].
37 Nelson RL, Thomas K, Morgan J, et al. Non surgical therapy for anal fissure. Cochrane Database Syst Rev. 2012;2(2). CD003431. [pmid: 22336789].
38 Nuesch E, Rutjes AW, Husni E, et al. Oral or transdermal opioids for osteoarthritis of the knee or hip. Cochrane Database Syst Rev. 2009;(4). CD003115. Epub: 2009/10/13. [pmid: 19821302].
39 Pandian Z, Marjoribanks J, Ozturk O, et al. Number of embryos for transfer following in vitro fertilisation or intra-cytoplasmic sperm injection. Cochrane Database Syst Rev. 2013;7(7). CD003416. [pmid: 23897513].
40 Pani PP, Trogu E, Vecchi S, et al. Antidepressants for cocaine dependence and problematic cocaine use. Cochrane Database Syst Rev. 2011;(12). CD002950. [pmid: 22161371].
41 Paul M, Dickstein Y, Schlesinger A, et al. Beta-lactam versus beta-lactam-aminoglycoside combination therapy in cancer patients with neutropenia. Cochrane Database Syst Rev. 2013;6(6). CD003038. [pmid: 23813455].
42 Perez MI, Musini VM, Wright JM. Effect of early treatment with anti-hypertensive drugs on short and long-term mortality in patients with an acute cardiovascular event. Cochrane Database Syst Rev. 2009;(4). CD006743. [pmid: 19821384].
43 Rehman H, Bezerra CC, Bruschini H, et al. Traditional suburethral sling operations for urinary incontinence in women. Cochrane Database Syst Rev. 2011;(1). CD001754. Epub: 2011/01/21. [pmid: 21249648].
44 Wilhelmus KR. Antiviral treatment and other therapeutic interventions for herpes simplex virus epithelial keratitis. Cochrane Database Syst Rev. 2010;(12). CD002898. [pmid: 21154352].
45 Shojania KG, Sampson M, Ansari MT, et al. Updating Systematic Reviews. Technical Review No. 16. AHRQ Publication No. 07-0087. Rockville, MD. Agency for Healthcare Research and Quality. Sep. 2007. http://www.ncbi.nlm.nih.gov/pubmed/20734512.
46 McGeechan K, Macaskill P, Irwig L, et al. Assessing new biomarkers and predictive models for use in clinical practice: a clinician's guide. Arch Intern Med. Nov. 24. 2008;168(21):2304-10. Epub: 2008/11/26. [pmid: 19029492].
47 Hosmer DW, Lemeshow S. Goodness of fit tests for the multiple logistic regression model. Communications in Statistics - Theory and Methods. 1980;9(10):1043-69.
48 Tripepi G, Jager KJ, Dekker FW, et al. Statistical methods for the assessment of prognostic biomarkers (Part I): discrimination. Nephrol Dialysis Transplant. May. 2010;25(5):1399-401. Epub: 2010/02/09. [pmid: 20139066].
49 Harrell J. F.E. Package ‘Hmisc’. 2014. http://cran.r-project.org/web/packages/Hmisc/Hmisc.pdf. December 19, 2014.
50 Mustafa RA, Santesso N, Brozek J, et al. The GRADE approach is reproducible in assessing the quality of evidence of quantitative evidence syntheses. J Clin Epidemiol. Jul. 2013;66(7):736-42 e5. [pmid: 23623694].
51 Schunemann HJ, Best D, Vist G, et al. Letters, numbers, symbols and words: how to communicate grades of evidence and recommendations. CMAJ. Sep. 30. 2003;169(7):677-80. [pmid: 14517128].