# Methods

We used a meta-epidemiological approach based on large, systematically appraised bodies of evidence that authors of Cochrane reports had graded as high SOE. We used effect estimates of such bodies of evidence as reference points because a grade of high SOE implies that investigators were very confident that the estimate of effect is close to the truth and that new studies are unlikely to change conclusions. Thus, we used these estimates as “gold standards” to determine the predictive validity. We did not assess the correctness of SOE grades in the Cochrane reports because we wanted to take a pragmatic perspective using real-world examples rather than an explanatory perspective using an ideal dataset. We assumed that users of systematic reviews would also take grades of SOE at face value.

## Assembling Empirical Data

We searched the Cochrane Library from 2010 onward to find Cochrane reports that: (1) include an outcome with more than eight randomized controlled trials (RCTs) on therapeutic interventions that had been graded as high SOE; (2) present meta-analytic outcomes that were reported as relative risks or odds ratios for binary outcomes or as weighted mean differences or standardized mean differences (SMDs) for continuous outcomes; and (3) provide data to reproduce the meta-analyses. We chose a threshold of eight RCTs so that we had enough studies to meta-analyze portions of these bodies of evidence in a chronological order of publication.

Overall, we drew information from 37 Cochrane reports on 50 bodies of evidence that had been graded as high SOE. Table 2 presents characteristics of these bodies of evidence.

Table 2 Cochrane reports and characteristics of high-strength bodies of evidence used to prepare summary documents

Cochrane Report | Intervention and Outcome | Number of Participants | Effect Estimate (Confidence Interval)
Amato et al., 2010^9^ | Benzodiazepines and adverse events | 471 | RR: 1.50 (0.83 to 2.70)
Amato et al., 2010^9^ | Benzodiazepines and dropouts | 839 | RR: 1.10 (0.75 to 1.63)
Amato et al., 2011^10^ | Psychosocial maintenance intervention and retention in treatment | 2,582 | RR: 1.02 (0.97 to 1.07)
Amato et al., 2013^11^ | Tapered methadone and completion of treatment | 1,381 | RR: 1.08 (0.97 to 1.21)
Buchleitner et al., 2012^12^ | Perioperative glycemic control and mortality | 1,365 | RR: 1.19 (0.89 to 1.59)
Chauhan et al., 2014^13^ | Long-acting beta agonists and exacerbations | 6,257 | RR: 0.87 (0.76 to 0.99)
Chin et al., 2013^14^ | Infraclavicular block and adequate surgical anesthesia | 1,051 | RR: 0.88 (0.51 to 1.52)
Chin et al., 2013^14^ | Infraclavicular block and tourniquet pain | 615 | RR: 0.66 (0.47 to 0.92)
Chin et al., 2013^14^ | Infraclavicular block and need for supplemental local anesthetic blocks or systemic analgesia | 1,412 | RR: 0.95 (0.62 to 1.46)
Chong et al., 2013^15^ | Phosphodieserase-4-inhibitors and exacerbations | 15,035 | OR: 0.77 (0.71 to 0.83)
Chong et al., 2013^15^ | Phosphodieserase-4-inhibitors and gastrointestinal side effects | 15,241 | OR: 3.07 (2.66 to 3.53)
Clifford et al., 2012^16^ | Autologous adult stem cells and left-ventricular ejection fraction | 879 | WMD: 1.78 (0.27 to 3.28)
Feagan et al., 2012^17^ | Oral 5-aminosalicylic acid and failure to maintain remission | 1,298 | RR: 0.69 (0.62 to 0.77)
Fernandes et al., 2013^18^ | Systemic or inhaled glucocorticoids and rate of hospital admission | 1,762 | RR: 0.92 (0.78 to 1.08)
Fernandes et al., 2013^18^ | Systemic or inhaled glucocorticoids and length of hospital stay | 633 | WMD: -0.18 (-0.39 to 0.04)
Gafter et al., 2012^19^ | Antibiotic prophylaxis and mortality | 5,635 | RR: 0.66 (0.55 to 0.79)
Gowing et al., 2009^20^ | Buprenorphine and completion of withdrawal treatment | 1,206 | RR: 1.64 (1.31 to 2.06)
Griffiths et al., 2013^21^ | Inhaled anticholinergic drugs and hospital admission | 2,497 | RR: 0.73 (0.63 to 0.85)
Gurion et al., 2012^22^ | Colony stimulating factors and mortality | 3,405 | RR: 1.03 (0.99 to 1.07)
Hauser et al., 2013^23^ | Serotonin and noradrenaline reuptake inhibitors and 50% pain reduction in fibromyalgia | 5,994 | RR: 1.49 (1.35 to 1.64)
Hauser et al., 2013^23^ | Serotonin and noradrenaline reuptake inhibitors and withdrawals due to adverse events | 6,179 | RR: 1.83 (1.53 to 2.18)
Hemmingsen et al., 2013^24^ | Intensive glycemic control and hypoglycemia | 28,127 | RR: 2.05 (1.39 to 3.02)
Hodson et al., 2013^25^ | Antiviral prophylaxis and cytomegalovirus disease (patients with organ transplants) | 1,132 | RR: 0.42 (0.32 to 0.57)
Hodson et al., 2013^25^ | Antiviral prophylaxis and cytomegalovirus disease (all treated patients) | 1,981 | RR: 0.42 (0.34 to 0.52)
Howe et al., 2011^26^ | Exercise and change in bone mineral density | 1,441 | WMD: 0.08 (-1.08to 0.92)
Katalinic et al., 2010^27^ | Stretch interventions and joint mobility | 221 | WMD: 1.00 (0.00 to 3.00)
Lai et al., 2013^28^ | Antimicrobial impregnation, coating, or bonding and mortality | 2,371 | RR: 0.88 (0.75 to 1.05)
Lai et al., 2013^28^ | Antimicrobial impregnation, coating, or bonding and adverse effects | 3,003 | RR: 1.09 (0.94 to 1.27)
Law et al., 2013^29^ | Sumatriptan plus naproxen and pain free at 2 hours | 3,370 | RR: 2.76 (2.43 to 3.13)
Law et al., 2013^29^ | Sumatriptan plus naproxen and pain free at 24 hours | 3,396 | RR: 3.04 (2.59 to 3.56)
Lemiengre et al., 2012^30^ | Antibiotics and cure from rhinosinusitis | 1,687 | OR: 1.25 (1.02 to 1.53)
Lemiengre et al., 2012^30^ | Antibiotics and treatment failure | 2,175 | OR: 0.49 (0.36 to 0.66)
Lewis et al., 2013^31^ | Nonsteroidal anti-inflammatory drugs and vomiting | 1,021 | RR: 0.72 (0.61 to 0.85)
Liakopoulos et al., 2012^32^ | Statins and atrial fibrillation | 841 | OR: 0.55 (0.44 to 0.69)
Liakopoulos et al., 2012^32^ | Statins and length of stay in hospital | 877 | RR: -0.48 (-0.85 to -0.11)
Main et al., 2013^33^ | Hormone therapy and stroke | 33,197 | RR: 1.26 (1.11 to 1.43)
Moja et al., 2012^34^ | Trastuzumab and congestive heart failure | 10,281 | RR: 5.11 (3 to 8.72)
Musini Vijaya et al., 2009^35^ | Pharmacotherapy and cardiovascular morbidity and mortality | 23,094 | RR: 0.72 (0.68 to 0.77)
Nannini et al., 2013^36^ | Long-acting beta2-agonist+inhaled corticosteroid and mortality | 7,518 | OR: 0.78 (0.64 to 0.94)
Nelson et al., 2012^37^ | Surgical therapy of anal fissure and healing | 979 | OR: 0.11 (0.06 to 0.23)
Nüesch et al., 2010^38^ | Opioids and withdrawal because of adverse events | 2,403 | RR: 4.05 (3.06 to 5.38)
Pandian et al., 2013^39^ | Double embryo transfer and live birth rate | 1,564 | OR: 2.07 (1.68 to 2.57)
Pandian et al., 2013^39^ | Double embryo transfer and multiple pregnancy rate | 1,612 | OR: 8.47 (4.97 to 14.43)
Pani et al., 2011^40^ | Antidepressant medication and alcohol abstinence | 942 | RR: 1.22 (0.99 to 1.51)
Paul et al., 2013^41^ | Antibiotic therapy and death in cancer patients with neutropenia | 7,186 | RR: 0.87 (0.75 to 1.02)
Paul et al., 2013^41^ | Antibiotic therapy and nephrotoxicity in cancer patients with neutropenia | 6,608 | RR: 0.45 (0.35 to 0.57)
Perez et al., 2009^42^ | Angiotensin converting enzyme inhibitors and mortality | 84,311 | RR: 0.93 (0.87 to 0.98)
Perez et al., 2009^42^ | Beta-blockers and mortality | 71,457 | RR: 0.96 (0.91 to 1.02)
Rehman et al., 2011^43^ | Traditional suburethral sling procedures and incontinence | 693 | RR: 0.97 (0.78 to 1.2)
Wilhelmus et al., 2010^44^ | Antiviral therapies and healing of herpes simplex virus keratitis | 401 | RR: 1.96 (1.67 to 2.31)

OR = odds ratio; RR = relative risk; SMD = standardized mean differences, WMD = weighted mean differences

## Preparing “Gradeable” Documents

From each of the 50 included bodies of evidence, we used portions in a chronological order of publication to prepare a total of 160 documents (which we called “gradeable” documents) reflecting different SOE categories. Sample size calculations indicated that 130 documents would provide 80 percent power for a 4 × 2 chi-square test of SOE (high, medium, low, or insufficient) by stability of results (stable vs. not stable) for a medium-sized effect (Cohen's d of 0.3) as a threshold for stability.

In a first step, we reanalyzed each body of evidence using cumulative meta-analyses. In general, a cumulative meta-analysis shows how the body of evidence evolves over time as new studies accrue. Likewise, the SOE changes (or can be expected to change) over time as new studies contribute to the body of evidence. Using information from the cumulative meta-analyses and information about individual studies from the Cochrane reports (e.g., risk of bias ratings), an independent investigator (who was not involved in the subsequent grading of the SOE) meta-analyzed the portions of the high-strength bodies of evidence in a chronological order (e.g., the first four studies, the first six studies, etc.) to prepare the gradeable documents.

Figure 1 illustrates this concept. The investigator took risk of bias of individual studies, precision of estimates, consistency of studies, indirectness, and the other domains of the grading scheme into consideration to decide what portions of studies were used for the gradeable documents.

Figure 1 Illustration of the concept of using portions of studies to create bodies of evidence to grade

CI = confidence interval; SOE = strength of evidence

Figure 1. lists the study name (Studies 1-10) and cumulative statistics (point, lower limit and upper limit) and the cumulative risk ration (95% confidence interval) for high, moderate, low and insuffient strength of evidence.

The aim was to create approximately 40 documents for each category of SOE with sufficient information for the project's investigators to grade the SOE. These documents included: information on the objective of the Cochrane review; the PICO (population-intervention-control-outcome); study characteristics and risk of bias ratings of included trials as presented in the Cochrane report; a forest plot of a random effects meta-analysis; information about minimal important differences for continuous outcomes; and information about reporting bias (funnel plot, Kendell's tau, Egger's regression intercept, and Fail-Safe N). We relied on judgments of the Cochrane authors regarding risk of bias of individual trials. We pilot-tested the format and content of the gradeable documents and revised them based on feedback from investigators. Appendix A provides an example of a gradeable document.

## Grading Strength of Evidence

To grade the SOE, investigators used EPC guidance for GRADE. Investigators took part in a calibration exercise and had access to a published guidance document.4

We randomly allocated 160 gradeable documents to 13 investigators from six U.S. and Canadian EPCs and Cochrane Austria. All are professional systematic reviewers; however, their experience with GRADE varied. Three investigators (23 percent) stated that they had used the GRADE approach for more than 20 systematic reviews; three (23 percent) used the approach for 10 to 15 systematic reviews; one (8 percent) used the approach for 6 to 10 reviews; and six investigators (46 percent) declared that they had used GRADE for up to 5 systematic reviews.

A research associate at RTI International connected each participant with a unique identification number and emailed the gradeable documents. This research associate was not involved in either the grading exercise or analysis of results. Two investigators, blinded to the results of the underlying Cochrane report (i.e., the reference standard), graded each body of evidence independently. Investigators were blinded to the second person grading the same body of evidence. When grades differed, the research associate put investigators in contact with each other; investigators resolved conflicts by consensus or by involving a third, senior researcher.

## Assessing the Stability of Effect Estimates

To determine the stability of effects, we compared effect estimates of the gradeable documents with the high SOE estimates from the Cochrane reports (the gold standard). To do so, we modified an approach developed to detect signals for updating systematic reviews.45 We used three definitions of stability (Table 3), which differed in the thresholds that determined whether the magnitude of treatment effects was similar. We deemed an estimate of effect as stable when (1) statistical significance did not change and (2) the magnitude of treatment effects remained similar to the high SOE estimate of the Cochrane report.

Table 3 Three definitions of stability of effect based on change in statistical significance and magnitude of effect

Stability of Effect: Definition 1 (Strict Definition)
Change in statistical significance | Statistical significance does not change between graded effect and gold standard effect (changes within the range of p-values 0.04 to 0.06 are not counted as change).
Change in magnitude of effect | Difference in magnitude of effects is smaller than a relative risk change (increase or reduction) of 25 percentage points for dichotomous outcomes or 0.20 SMDs for continuous outcomes.
Stability of Effect: Definition 2 (Lenient Definition)
Change in statistical significance | Same as definition 1.
Change in magnitude of effect | Difference in magnitude of effects is smaller than a relative risk change of 50 percentage points for dichotomous outcomes or 0.50 SMDs for continuous outcomes.
Stability of Effect: Definition 3 (Staggered Definition)
Change in statistical significance | Same as definition 1.
Change in magnitude of effect | - For graded effects with small treatment effects (relative risk 0.5 to 2.00, or SMD <0.8): Same as definition 1.; - For graded estimates with large treatment effects (relative risk <0.5 and >2.00, or SMD >0.8): Same as definition 2.; - For outcomes that can be considered extremely patient-relevant (e.g., mortality, stroke, myocardial infarction): Difference in magnitude of effects is smaller than relative risk change of less than 10 percentage points.

SMDs = standardized mean differences.

To avoid counting trivial or ‘borderline’ changes in statistical significance, we required that at least one of the two results had had a p-value outside the range of 0.04 to 0.06. In other words, we did not consider cases in which a p-value changed statistical significance within this range. For example, neither a change from p=0.041 to p=0.059 nor a change from p=0.059 to p=0.041 counted as a change in statistical significance.

## Conducting Statistical Analysis

To assess the inter-rater reliability of reviewers grading the SOE, we calculated intra-class correlations using a one-way random effects model. Intra-class correlations measure the consistency of agreement of reviewers when dually grading bodies of evidence.

To determine the predictive validity, we compared the expected proportion of stable effect estimates (presented in Table 1) with the observed proportion of stable effect estimates for different thresholds from our sample. Statistically, predictive validity can be determined by calculating two characteristics: (1) calibration and (2) discrimination. Calibration refers to the ability to estimate correctly the likelihood of a future event. In our study, calibration is the ability to determine the likelihood that estimates remain stable. Discrimination refers to the ability to differentiate between those that will experience a future event and those that will not. In our study, discrimination is the ability to differentiate between effect estimates that will remain stable and those that will substantially change.46

We determined the calibration of the EPC approach to GRADE with the Hosmer-Lemeshow test47 and its discrimination with the concordance (C) index. Bodies of evidence that remain stable should have higher expected likelihoods than those that do not. The C index compares the expected likelihoods from pairs of observations. In this case, the term “pairs” refers to stable versus not stable effect estimates, as shown below:48

C index = (# of concordant pairs + (1)/(2) ( # of tied pairs ))/(Total # of pairs) We determined the calibration of the EPC approach to GRADE with the Hosmer-Lemeshow test47 and its discrimination with the concordance (C) index. Bodies of evidence that remain stable should have higher expected likelihoods than those that do not. The C index compares the expected likelihoods from pairs of observations. In this case, the term “pairs” refers to stable vs. not stable effect estimates, as shown below. The C index equals the number of concordant pairs plus one half times the number of tied pairs) all divided by total number of pairs. :48; C index= (# of concordant pairs+1/2 (# of tied pairs))/(Total # of pairs); Concordant pairs are pairs for which the expected likelihood for the stable body of evidence is higher than the expected likelihood for the nonstable body of evidence. Tied pairs are pairs for which the stable and nonstable bodies of evidence have the same expected likelihood. Higher values for the C index indicate better discrimination. A C index of 0.50 would indicate no discrimination between stable and nonstable bodies of evidence. We conducted all statistical analyses with the rcorr.cens procedure in the Hmisc package in R49 or Microsoft Excel.

Concordant pairs are pairs for which the expected likelihood for the stable body of evidence is higher than the expected likelihood for the nonstable body of evidence. Tied pairs are pairs for which the stable and nonstable bodies of evidence have the same expected likelihood. Higher values for the C index indicate better discrimination. A C index of 0.50 would indicate no discrimination between stable and nonstable bodies of evidence. We conducted all statistical analyses with the rcorr.cens procedure in the Hmisc package in R49 or Microsoft Excel.