# Peer Reviewers

Prior to publication of the white paper, we sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified

The list of Peer Reviewers follows:

- Mohammed T. Ansari, M.B.B.S., M.Med.Sc., M.Phil.
  Clinical Meta-Research Methodologist and EBM Consultant
  Adjunct Professor, University of Ottawa
  Ottawa, Canada
- Rongwei (Rochelle) Fu, Ph.D.
  Pacific Northwest Evidence-based Practice Center
  Oregon Health & Science University
  Portland, OR
- Jennifer Graff, PharmD.
  National Pharmaceutical Council
  Washington, DC
- Gordon Guyatt, B.Sc., M.D. M.Sc., FRCPC, OC
  Department of Clinical Epidemiology & Biostatistics
  McMaster University
  Hamilton, Ontario, Canada
- Susan L. Norris, M.D., M.P.H.
  World Health Organization
  Geneva, Switzerland
- Evelyn Whitlock, M.D., M.P.H
  Kaiser Permanente Research Affiliates Evidence-based Practice Center
  Portland, OR