# Acknowledgments

The authors gratefully acknowledge the continuing support of our AHRQ Task Order Officer, Stephanie Chang, M.D., M.P.H. We would also like to thank Donna Dryden, Ph.D., University of Canada, Alberta; Marian McDonagh, PharmD., Oregon Health & Science University; Margaret Maglione, M.P.P., RAND Corporation; Barbara Nußbaumer, M.Sc., Danube University, Austria; and Jonathan Treadwell, Ph.D., ECRI Institute, for their contributions to this study. In addition, we thankfully acknowledge Evelyn Auer for administrative support and Loraine Monroe for document preparation support.