# Discussion

To our knowledge, our study was the first attempt to determine the predictive validity of the GRADE approach. To be considered useful in practice, any tool that conveys certainties and uncertainties of estimates of effect should have a high ability to discriminate between estimates that will remain stable in the future and those that will substantially change; it should also be able to associate respective likelihoods of stability with an expected outcome. Our research indicates that the EPC approach to GRADE only partly fulfilled these qualities of predictive validity: Only moderate SOE had satisfactory predictive validity. In the following sections, we discuss possible reasons for these findings and potential starting points for improving the predictive validity.

A predictive model, in general, is a mathematical equation describing the relationship between a prognostic marker (here, a grade of SOE) and a given outcome (stability of effect estimates).48 In our study, three main factors determined the predictive validity of the EPC approach to GRADE:

1. The definition of stability,
2. The likelihood of expected stability associated with each grade of SOE (the prognostic marker), and
3. The operationalization of the prognostic tool (the EPC approach to GRADE) to achieve the most appropriate prognostic marker (i.e., the grade of SOE).

With respect to the first factor, the definition of stability, our study showed that strict or lenient definitions of stability had minimal impact on the predictive validity of the EPC approach to GRADE. Therefore, the other two factors appear to be the reasons for the low predictive validity and could serve as starting points for future improvements.

To determine the proportion of stable estimates that users and producers of systematic reviews associate with each grades of SOE, we recently conducted an international survey that we used as the basis of the comparison between expected and observed proportions of stable results.6 The rationale for applying our survey results was that users of systematic reviews make decisions based on their individual interpretations of definitions of grades of SOE. If individual interpretations substantially over- or under-estimate the actual stability of effect estimates, decisions based on systematic reviews could be misguided.

Our findings indicate that, except for moderate SOE, the expectations of survey participants did not match results from our sample. Expectations were too optimistic for high SOE and too pessimistic for low and insufficient SOE. Current definitions of different grades of SOE, however, employ vague terminology to forecast certainty—such as “likely,” “very likely,” or “may be substantially different”—and this practice might contribute to the low predictive validity. Psychological research has demonstrated that perceptions of certainty can vary substantially among individuals, and that interpretation of qualitative certainty expressions also differ depending on the context in which they are used and on baseline event rates. Adding numerical predictions such as likelihoods to the definitions of the individual grades of SOE seems to be one solution that could reduce unwarranted variation in interpretations.

Finally, the EPC approach to GRADE, or the way systematic reviewers operationalize it, appears to be too strict. More than half of estimates graded as insufficient (defined as “we have no confidence in the estimate of effect for this outcome”) remained stable; this indicates that the approach too often leads to low or insufficient grades of SOE. Possible reasons could be: (a) systematic reviewers use GRADE too mechanistically, (b) recommended thresholds for downgrading in guidance documents are too strict, or (c) a tool with four levels of SOE is not granular enough to categorize uncertainty. Adding a fifth category—e.g., by using GRADE very low for bodies of evidence in which systematic reviewers still have some (albeit little) confidence and EPC's insufficient for bodies of evidence that have truly unacceptable deficiencies that preclude reaching a conclusion—would allow for more granularity.

Our study has several limitations. First, we relied on risk of bias assessments and SOE grades of Cochrane authors. Because author groups differed across these systematic reviews, heterogeneity in approaches and varying adherence to guidance documents regarding SOE grades is likely. For example, in about 20 percent of our sample (presented in Table 1), confidence intervals cross both the line of no effect and thresholds of appreciable benefits and harms. According to GRADE and EPC guidance, such a situation would require reviewers to grade down for imprecision. Nevertheless, we deliberately did not reassess SOE grades because we wanted to take a real-world, pragmatic perspective with our assessment of predictive validity. We assumed that most guideline developers or other decisionmakers who use Cochrane reports to support decisions also would not reassess SOE and would take respective grades at face value. In addition, Cochrane reports go through rigorous international peer review, and the methodological quality is usually high.

Second, how representative our sample is remains unclear. Because we wanted to use a reference standard for which researchers had high confidence that effect estimates are correct (close to the true effect), we focused on high SOE evidence. A remaining question is whether our findings are generalizable to bodies of evidence that will never progress to high SOE. In addition, our sample was limited to RCTs, so findings are likely not generalizable to research based on nonrandomized studies.

Third, systematic reviewers grading the SOE had access to guidance documents but they did not use a formal instrument such as the GRADEpro Guideline Development Tool (www.guidelinedevelopment.org) to navigate the grading exercises in a standardized manner. Using such a tool could increase inter-rater reliability and might reduce the number of grades of SOE that are too strict.50 In situations with conflicting grades, strong personalities (maybe with a tendency to strict grades) often dominate the consensus process. Increasing inter-rater reliability would reduce the number of situations that require systematic reviewers to reach a consensus.

Over the past decade, GRADE has evolved as a widely used approach to convey the certainties and uncertainties inherent in research. Its conceptual framework uses information about factors that most researchers would intuitively consider when assessing the confidence in findings based on a body of evidence. Compared with other approaches, GRADE has clear advantages because it makes decisions about the SOE transparent and explicit.51

The lack of predictive validity, therefore, is probably not grounded in the concept of GRADE but rather in the way the instrument is operationalized, which, overall, appears to be too strict. The GRADE Working Group, as well as organizations such as AHRQ EPCs, need to reflect on how to reduce unwarranted variation in the interpretation of the definitions of individual grades of SOE and how to avoid overly strict grades.

Future research needs to confirm or refute our findings and explore which domains may lead to excessively strict operationalization and influence the predictive validity of the GRADE approach. Future research also needs to test whether its predictive validity is satisfactory under ideal circumstances using bodies of evidence as reference standards that are undisputed in their high SOE grade and also have a low statistical likelihood of changing as future studies accrue. Such research also needs to examine whether more (or fewer) than four grades would better capture and communicate uncertainty of research findings.

Given the moderate inter-rater reliability in our study, the EPC guidance document on grading the strength of evidence might need to be revised to provide clearer advice on how to grade the individual domains. Qualitative research can explore areas that reviewers struggle with the most when applying the GRADE approach.