# Example Gradeable Document

Gradeable Document B-3-1.5-1

## General Information and Instructions

The information in this document is based on a published Cochrane review. Risk of bias ratings and decisions to include specific studies in the meta-analysis were those of the Cochrane review authors. The current document summarizes:

1. the objectives of the Cochrane review,
2. the PICOs (population, intervention, comparator, outcome),
3. the risk of bias ratings for each included study,
4. the forest plot of a random effects meta-analysis (for dichotomous outcomes the effect measure is the risk ratio, for continuous outcomes the standardized mean difference), and
5. the funnel plot of the meta-analysis.
6. The appendix provides more detail on the individual studies as presented in the Cochrane report.

Please use this information and the EPC guidance to grade the strength of evidence for the presented outcome.

## Objective of Review

To examine the effectiveness of exercise in preventing bone loss in postmenopausal women by determining whether or not exercise slows bone loss and has a beneficial effect on the axial (the skull, spine and rib cage) and appendicular (the bones of the limbs and pelvis) bone density in postmenopausal women.

## PICOs

### Population of Interest

Healthy postmenopausal women (including those with previous fractures) aged between 45 and 70 years.

### Intervention

Exercise program (e.g. walking, calisthenics and resisted strengthening)

### Comparator

Standard therapy (e.g. usual activity or placebo with or without pharmacological consumption).

### Outcome

Bone mineral density % change: hip

Minimal important difference (MID): Authors provide no information on MID

## Risk of Bias of Included Studies (as assessed by authors of review)

All included studies were RCTs

This figure illustrates the level of bias by all studies and the chracteristics of the study quality

Funding of included studies: no information reported

This figure is a colored chart of the funding of included studies and reports no information reported and the percentage of risk based on the study risk characteristics. The second graph is the summary effect of the intervention and illustrates the random effects of meta-analysis which is the standardized mean difference of bone mineral (hip) density percentage change.

## Summary Effect of the Intervention

Random effects meta-analysis: standardized mean difference of bone mineral density % change: hip

The first figure was a colored chart of the funding of included studies and reports no information reported and the percentage of risk based on the study risk characteristics. This second graph is the summary effect of the intervention and illustrates the random effects of meta-analysis which is the standardized mean difference of bone mineral (hip) density percentage change.

## Publication Bias

[underlined: Selective reporting:] Insufficient information was available to permit judgement of ‘low risk’ or ‘high risk of bias’ for selective reporting for any of the 43 studies.

This funnel plot describes the Selective reporting. Insufficient information was available to permit judgement of ’low risk’ or ‘high risk of bias’ for selective reporting for any of the 43 studies. The Y-axis shows the standard error on a 0.10 scale from 0.5 to 0.0 and the X-axis shows the standard difference in means on a scale of -3 to 3 in increments of 1.

Kendell's tau (with continuity correction, 2-tailed) | P-value: 0.35
Egger's regression intercept | P-value: 0.12
Fail-Safe N | Number of missing studies that would bring P-value to >0.05: 0

## Details of Included Studies

Bemben 2000

Each table reflects the details of one included study. Two columns table with a title for each row name 1) methods 2) particpants 3) interventions 4) outcomes 5) notes in the first colun and the study information in the second column. The bottom section of the table has another section for risk of bias in one column and underneath that three columns for 1) bias 2) author's judgements and 3) support for judgements with acommpanying informaiton about each from the study in the rows beneath it.

Bergstrom 2008

Each table reflects the details of one included study. Two columns table with a title for each row name 1) methods 2) particpants 3) interventions 4) outcomes 5) notes in the first colun and the study information in the second column. The bottom section of the table has another section for risk of bias in one column and underneath that three columns for 1) bias 2) author's judgements and 3) support for judgements with acommpanying informaiton about each from the study in the rows beneath it.

Cheng 2002

Each table reflects the details of one included study. Two columns table with a title for each row name 1) methods 2) particpants 3) interventions 4) outcomes 5) notes in the first colun and the study information in the second column. The bottom section of the table has another section for risk of bias in one column and underneath that three columns for 1) bias 2) author's judgements and 3) support for judgements with acommpanying informaiton about each from the study in the rows beneath it.

Chilibeck 2002

Each table reflects the details of one included study. Two columns table with a title for each row name 1) methods 2) particpants 3) interventions 4) outcomes 5) notes in the first colun and the study information in the second column. The bottom section of the table has another section for risk of bias in one column and underneath that three columns for 1) bias 2) author's judgements and 3) support for judgements with acommpanying informaiton about each from the study in the rows beneath it.

Kerr 2001

Each table reflects the details of one included study. Two columns table with a title for each row name 1) methods 2) particpants 3) interventions 4) outcomes 5) notes in the first colun and the study information in the second column. The bottom section of the table has another section for risk of bias in one column and underneath that three columns for 1) bias 2) author's judgements and 3) support for judgements with acommpanying informaiton about each from the study in the rows beneath it.

Korpelainen 2006

Each table reflects the details of one included study. Two columns table with a title for each row name 1) methods 2) particpants 3) interventions 4) outcomes 5) notes in the first colun and the study information in the second column. The bottom section of the table has another section for risk of bias in one column and underneath that three columns for 1) bias 2) author's judgements and 3) support for judgements with acommpanying informaiton about each from the study in the rows beneath it.

Maddalozzo 2007

Each table reflects the details of one included study. Two columns table with a title for each row name 1) methods 2) particpants 3) interventions 4) outcomes 5) notes in the first colun and the study information in the second column. The bottom section of the table has another section for risk of bias in one column and underneath that three columns for 1) bias 2) author's judgements and 3) support for judgements with acommpanying informaiton about each from the study in the rows beneath it.

Newstead 2004

Each table reflects the details of one included study. Two columns table with a title for each row name 1) methods 2) particpants 3) interventions 4) outcomes 5) notes in the first colun and the study information in the second column. The bottom section of the table has another section for risk of bias in one column and underneath that three columns for 1) bias 2) author's judgements and 3) support for judgements with acommpanying informaiton about each from the study in the rows beneath it.

Pruitt 1996

Each table reflects the details of one included study. Two columns table with a title for each row name 1) methods 2) particpants 3) interventions 4) outcomes 5) notes in the first colun and the study information in the second column. The bottom section of the table has another section for risk of bias in one column and underneath that three columns for 1) bias 2) author's judgements and 3) support for judgements with acommpanying informaiton about each from the study in the rows beneath it.

Verschueren 2004

Each table reflects the details of one included study. Two columns table with a title for each row name 1) methods 2) particpants 3) interventions 4) outcomes 5) notes in the first colun and the study information in the second column. The bottom section of the table has another section for risk of bias in one column and underneath that three columns for 1) bias 2) author's judgements and 3) support for judgements with acommpanying informaiton about each from the study in the rows beneath it.

Von Stengel 2009

Each table reflects the details of one included study. Two columns table with a title for each row name 1) methods 2) particpants 3) interventions 4) outcomes 5) notes in the first colun and the study information in the second column. The bottom section of the table has another section for risk of bias in one column and underneath that three columns for 1) bias 2) author's judgements and 3) support for judgements with acommpanying informaiton about each from the study in the rows beneath it.