# Technical and Informatics Issues

## What Types of Wikis Are Available?

Different types of wikis are available with a range of features but all are server-based. The server can be maintained by the user or by a hosting organization. There are a large number of open-source wikis, and even commercial products are frequently free for personal use. Enterprise wikis are a single framework for managing multiple wikis. These are designed for the easy creation and management of new wiki spaces under a single organizational umbrella. These systems can link into existing user account repositories which allow users to log in using their organizational logon and password information.2 WikiMatrix is an online site that allows users to compare wikis on more than 90 features. Lists of these features are presented in Appendix B.

Most people are familiar with Wikipedia, the wiki-based collaboratively maintained free-content encyclopedia project. Wikipedia can be edited by anyone with Internet access. But this does not have to hold true for all wikis. Wikis can differ in their community structures in several ways. Wikipedia represents an all-virtual community in which membership is granted by virtue of participating in the community. But wikis can also reflect existing physical and hybrid communities. In these cases, there are elements that tie the members together outside of participating in the wiki. Examples of these communities would include people working for the same organization, people with shared goals, and working groups. Levels of access can be tailored to meet the needs of the community and can range from completely open access to participation by invitation only.

Semantic wikis have been proposed as a means of enriching links with meaning.25-29 A detailed discussion of ontologies, modeling, and description logic is outside the scope of this report. However, Wagner et al.'s discussion of building semantic webs for e-government with wiki technology may be of interest. The authors note that government domains are very large and include much information created by heterogeneous distributed sources. This results in inconsistent terminology and information overload. They propose overcoming this by adding a logic layer or semantic infrastructure for meaningful organization. This semantic layer would be maintained separately from the content, which allows continued collaborative development by nontechnical users. In their proposed approach “…site developers …annotate the Web pages with semantic markup, semantic links, and metadata so as to enable machines to follow the links and ideally to facilitate the integration of knowledge and information from many different sources.” 27(). Semantic markup refers to a markup language whose name spaces, vocabulary and relationships are meaningfully definable. Semantic links are pointers between Web objects, which can be meaningfully interpreted because of their labeling elsewhere in the system and because they may have properties or methods associated with them. The metadata adds further well-defined, meaningful information so as to facilitate machine readability even more and to enable better Web analysis to furnish best results to citizen users.” Semantic wiki platforms are under development and semantic extensions for commonly used wikis (such as MediaWiki) are available.

## Uses for Wikis

Szybalski21 describes the wiki as the “conceptual descendant of both online communication networks like Usenet and application software like the word processor.” Given the wiki's ease of access and its ability to foster collaboration, wikis have been used in many contexts, most of which involve project management and/or content creation and management.

Majchrzak et al30 surveyed experienced corporate wiki users to determine whether wikis were considered sustainable and beneficial and to characterize contributors and contributions. They found that wikis were used for:

- software development
- e-learning
- project management
- posting information
- knowledge management
- communities of practice/user groups
- ad hoc collaboration
- tech support
- marketing/customer relationship management
- resource management
- R&D

Topic-specific wiki-based resources are also common. Medpedia,31 a wiki-based medical resource that launched recently clearly lays out commonly accepted principles of wiki participation. According to the Web site:

The goal of The Medpedia Project is to evolve a new model for how the world will access medical knowledge in the future. The specifics of the model will evolve over time, but Medpedia is founded on several principles that will remain:

- Wisdom of the Many—Medpedia is an iterative environment where content is written, edited and constantly re-edited by an ever-larger group of editors. Hundreds of editors can read the articles and monitor changes using the “Recent Changes” pages. The model, therefore, is that incorrect information will be corrected quickly, and the overall accuracy of Medpedia will always be improving.
- Collaborative—Medpedia gives consumers, medical professionals, and organizations/companies their own ways to contribute. Each has a role in the real world, and each can be effective in contributing to Medpedia. The tools and permissions for those contributions will evolve over time as the system matures.
- Interdisciplinary—Medpedia is able to tap knowledge from all medical and health professionals, starting with physicians and Ph.D. researchers, but safely including anyone with expertise and motivation, including nurses, public health officials, social workers, etc.
- Appropriate language—Medpedia provides a structured environment encouraging two types of content to emerge: “Plain English” pages for the layperson, and “Clinical” pages for medical professionals.
- Transparent—All members must have a profile with their real names and must disclose any financial, personal, or professional affiliations that may influence their participation on Medpedia. Every change made to the site is attached to a member's profile, and every change is visible in the logs of the knowledge base.
- Self Service—Medpedia is a platform of free tools anyone can use. Medical professionals can use Medpedia as a knowledge-sharing and communications tool, a recruiting tool for research collaborators, a clinical referral network, an article-publishing network, and a way to develop their reputation in their areas of expertise. Organizations can use Medpedia as a communications tool for their members and to fulfill their mission. And anyone may use Medpedia set alerts to follow topics of interest, learn and collect knowledge, teach and share information and elevate the best medical information on the Web.
- Free, Web-based, Real Time—Due to the nature of the Web, improvements made on the Web site are immediately available worldwide for zero incremental cost.”

In addition to corporate, academic and general public use, wikis have also been implemented for government use both within specific agencies and on the broader federal level. These will be discussed in more detail in the section on Government Wikis.

## Best Practices in Wiki Design

Wikis are intended to be graphically simple, but there are still design principles that encourage adoption and facilitate use. The core of the “Wiki Way” is represented by the following principles:27

Open—Any reader can edit as s/he sees fit.

- Incremental—Pages can cite other pages, including pages that have not been written yet. Within wiki systems citing the page will cause it to be created.
- Organic—Structure and text content of the site is open to editing and evolution.
- Mundane—A small number of (irregular) text conventions will provide access to the most useful (but limited) page markup.
- Universal—Mechanisms of editing and organizing are the same as those of writing so that any writer is automatically an editor and organizer.
- Overt—The formatted (and printed) output will suggest the input required to reproduce it (e.g., location of the page).
- Unified—Page names are drawn from a flat space so that no additional context is required to interpret them.
- Precise—Pages will be titles with sufficient precision to avoid most name clashes, typically by forming noun phrases.
- Tolerant—Interpretable (even if undesirable) behavior is preferred to error messages.
- Observable—Activity within the site can be watched and reviewed by any other visitor to the site.
- Convergent—Duplication can be discouraged or removed by finding and citing similar or related content.

In Wikipatterns,5 Mader provides a list of best practices for pilot implements and for broader adoption.

Pilots

- Establish a timeframe (∼3–6 months)
- Make it representative. Ensure you choose groups that represent typical projects and activities. This enhances buy in and provides a cross-section for evaluation.
- Keep the pilot groups small so you can work closely with each one.
- Choose representatives from each potential user group.
- Determine whether you'll hand-pick participants or advertise.
- Wikis must have a purpose to be relevant.
- Set up basic rules or guidelines.
- Set up personal spaces for each participant (contact information, blog/personal URL, biography).
- Encourage users to create scaffolds (templates) for new pages.
- “Make it a magnet”—get people into the habit of looking at the wiki for their information. You can accomplish this is by emailing links to the content on the wiki rather than the content itself.
- “Be firm and think long term”—try to keep users from slipping back into old habits (e.g., e-mail).

For wider adoption, Mader recommends developing a wiki use policy and adds the following items to the list created for pilots:

- Don't make the policy too long to read in its entirety.
- Note the goal for the wiki.
- Note there needs to be a moderator for each space—this helps to nurture growth, maintain organization, and provide a point of contact. However, he cautions moderators to remember that the space is owned by the community first and foremost and resist controlling it.
- Consider information sensitivity. This includes determining the visibility of information and the level of confidentiality required. There should be disclosure policy posted within each unit.
- Use disclaimers—consider consequences of posting information and consider that it's not just what is said but how it is said.

Overall, he recommends taking a phased approach, explaining how the wiki will help users and offering training and user support.

Hohman and Saiedian3 discuss methods of customizing wikis to enhance project management. In addition to core activities such as posting and authoring content, they suggest incorporating pages for the following elements:

- Rapid feedback areas—These encourage quick turnaround on evaluation of work products and should involve both management and peers.
- Peer-to-Peer links—The authors suggest three levels: upper management, project management, and developers. The goal is facilitating communication between groups by making it easy to know who to contact in the other groups. The information should include the easiest method of contacting each person.
- Role descriptions—Explicitly defining user roles facilitates communication between nonpeers. The authors strongly suggest creating the role of Problem Solver—this would be a highly experienced team member who either knows most of the answers to questions about the project or knows where to find them. There should be one problem solver per team, and everyone on the team should know who holds that role.
- High-level reports—Posting project status and progress reports with a broad focus can serve multiple purposes. These include providing context for upper management and developers, providing a backup means of communicating project-related changes and decisions to remote teams, and alerting group members when documents or other information needed for the next stage of the project become available.
- Face lists—Posting photos and an organizational chart builds trust between groups and combats the feeling that “remote team members are unknown and easily disregarded partners.”
- Project directory—These pages should contain definitions for key terms and jargon as well as lay out the methodology for the project. It should also provide background and context for the project.
- Business rules and policies—These pages should contain links to formal documents and list rules and policies that are not defined more formally.
- Semantic wikis—The authors suggest using two levels of semantic data (applied in the form of tags). The first level would be project oriented. For example, a Gantt chart for resource allocation would be labeled with a scheduling tag while schema planning notes would be labeled with an architectural planning tag. The second level of semantics would be chosen by the users. The authors note that while semantic tags are useful adjuncts for wiki content, they should be optional to prevent discouraging users from adding content.
- Light constraints—According to Di Iorio and Zacchiroli,32 wiki editing involves implicit rules that are exemplified by the editing practices of wiki users. Heavy constraints are “constraints that wiki pages must satisfy at any given instant to be practically useful.” They note the need to code wiki pages so that they can be parsed by the wiki engine as an example of heavy constraints. Light constraints can be “(temporarily or not) violated, without inhibiting proper wiki runtime behavior.” Light constraints typically encode community best practices and domain-specific requirements. They apply to the content itself rather than metadata or URLs and in some cases can be achieved using templates. The authors note several areas where this can help contributors and enhance consistency across the wiki. These scenarios include verifying spelling words, providing guidance for managing intra-wiki links, and creating a standard user profile that becomes available when contributors join the wiki community. They note that nonadherence to the constraints shouldn't prevent contributors from saving their content, but should be noted for reference. A user role of “Tailor” is suggested by both Hohman and Di Iorio—only users with a Tailor designation would be able to edit the rules for the constraints.3,32