# References

1 Oxford English Dictionary Online Project Team. Definition of “wiki” Oxford English Dictionary Online. New York. Oxford University Press. 2007. Available at: http://dictionary.oed.com. December 12, 2008.
2 Choate MS. Professional wikis. Indianapolis. Wiley Publishing, Inc. 2008.
3 Hohman J, Saiedian H. Wiki customization to resolve management issues in distributed software projects, Crosstalk. Aug. 2008:1-8. Available at: http://www.stsc.hill.af.mil/crosstalk/2008/08/0808HohmanSaiedian.html.
4 Guy M. Wiki or won't he? A tale of public sector wikis, Ariadne. Oct. 2006;(49):1-11. Available at: http://www.ariadne.ac.uk/issue49/guy.
5 Mader S. Wikipatterns. Indianapolis. Wiley Publishing, Inc. 2008.
6 Wenger EC, Snyder WM. Communities of practice: the organizational frontier, Harvard Business Review. Jan-Feb. 2000:139-5. Available at: http://www.stevens-tech.edu/cce/NEW/PDFs/commprac.pdf.
7 EbM in quality management and operational medicine. 8th Annual Meeting of the German network e. V. Evidence-based medicine. 2007 Mar 22-24. Berlin (DE). Duesseldorf, Cologne, DE. German Medical Science. Mar. 15. 2007:3. Available at: http://www.egms.de/en/meetings/ebm2007/07ebm006.shtml.
8 Huss JW, Orozco C, Goodale J, et al. A gene wiki for community annotation of gene function. PLoS Biol. Jul. 8. 2008;6(7):e175. [pmid: 18613750].
9 Hill MD, Gaudiot JL, Hall M, et al. A wiki for discussing and promoting best practices in research. Commun Acm. Sep. 2006;49(9):63-4.
10 Wilder H, Ferris SP. Using a wiki to write about wikis. J Electron Pub. 2007;10(2).
11 Noel S, Robert JM. How the web is used to support collaborative writing. Available at: http://charlie.res.crc.ca/∼sylvie/Articles/BIT_02_05_2003.pdf. February 23, 2009.
12 Liccardi I. CAWS: improving users' awareness in collaborative authoring activities. Group ‘07 Doctoral Consortium papers. November 4–7, 2007. Sanibel Island (FL). Association for Computing Machinery. 2007. Article No. 6.
13 Liccardi I, Davis HC, White S. CAWS: a wiki system to improve workspace awareness to advance effectiveness of co-authoring activities. CHI ‘07 extended abstracts on human factors in computing systems. Conference on human factors in computing systems. April 28– May 3, 2007. San Jose (CA). Association for Computing Machinery, Inc. 2007:2555-2560. [doi: 10.1145/1240866.1241040].
14 Liccardi I, Davis HC, White S. CAWS: an awareness based wiki system to improve team collaboration. Eighth international conference on advanced learning technologies. 2008 Jul 1–5. IEEE Explore. 2008:265-7.
15 Kim EE. An introduction to Purple, version 1.3. 2001. Aug. 28. Available at: http://www.eekim.com/software/purple/purple.html. February 23, 2009.
16 Ignat CL, Oster G, Molli P, et al. A comparison of optimistic approaches to collaborative editing of wiki pages. Cedex (FR). Loria. 10. Available at: http://www.irisa.fr/asap/intranet/a-comparison-of-optimistic-approaches-to-collaborative-editing-of-wiki.pdf.
17 Viegas FB, Watenberg M, Dave K. Studying cooperation and conflict between authors with history flow visualizations. Conference on Human Factors in Computing Systems. Proceedings of the SIGCHI Conference on Human Factors in Computing Systems. 2004 April 24–29. Vienna, Austria. Association of Computing Machinery, Inc. 2004:575-82.
18 Kittur A, Suh B, Pendleton BA, et al. He says, she says: conflict and coordination in Wikipedia. CHI 2007 proceedings. 2007 April 28–May 3. San Jose (CA). Association for Computing Machinery. 2007:453-62. Available at: http://www-users.cs.umn.edu/…/2007-Wikipedia-coordination-PARC-CHI2007.pdf.
19 Burrow AL. Negotiating access within Wiki: a system to construct and maintain a taxonomy of access rules. Proceedings of the 15th ACM Conference on Hypertext and Hypermedia. 2004 August 9–13. Santa Cruz, CA. New York (NY). Association of Computing Machinery. 2004.
20 Suh B, Chi EH, Kittur A, et al. Lifting the veil: improving accountability and social transparency in Wikipedia with WikiDashboard. Proceedings of the 26th Annual SIGCHI Conference on Human Factors in Computing Systems. CHI ‘08 Conference on Human Factors in Computing Systems. 2008 April 5–10. Florence, Italy. Association of Computing Machinery, Inc. 2008:1037-40.
21 Szybalski A. Why it's not a wiki world (yet). 2005. Mar. 14. Available at: http://www.foo.be/docs-free/wiki_world.pdf.
22 Suvinen H, Saariluoma P. User psychological problems in a wiki-based knowledge sharing portal. Proceedings of the 3rd International Conference on Internet and Web Applications and Services. Washington (DC). IEEE Computer Society. 2008;2008:552-7.
23 Butler B, Joyce E, Pike J. Don't look now but we've created a bureaucrazy: the nature and roles of policies and rules in Wikipedia. Proceeding of the 26th Annual SIGCHI Conference on Human Factors in Computing Systems. 2008 April 5–10. Florence, Italy. New York (NY). Association of Computing Machinery (ACM). 2008.
24 Buzzi M, Leporini. Is Wikipedia usable for the blind?. Proceedings of the 2008 International Cross-Disciplinary Conference on Web Accessibility (W4A). W4A2008. 2008 April 21–22. Beijing, China. Association of Computing Machinery, Inc. 2008:15-22.
25 Aviero D, Mendes J, Tribolet J. Organizational modeling with a semantic wiki. Proceedings of the 2008 ACM Symposium on Applied Computing. Symposium on Applied Computing. 2008 March 16–20. Fortaleza, Ceara. Brazil Association of Computing Machinery. 2008:592-3.
26 Albers A, Sauter C, Meboldt M, et al. Semantic wikis in knowledge management for multidisciplinary product development. Katalinic B, editor. Annal of DAAAM for 2007 & Proceedings of the 18th International DAAAM Symposium. Vienna, Austria. DAAAM International. 2007:5-6.
27 Wagner C, Cheung KS, Ip RF, et al. Building semantic webs for e-government with Wiki technology. Elect Gov. 2006;3(1):36-55. [doi: 10.1504/EG.2006.008491].
28 Volkel M, Krotzsch M, Vrandecic D, et al. Semantic Wikipedia. Proceedings of the 15th International Conference on World Wide Web. International World Wide Web Conference. 2006 May 23–26. Edinburgh, Scotland. Association of Computing Machinery Inc. 2006:585-94.
29 Semantic Wikipedia. [Preprint submitted to Elsevier]. 2007. Aug. 31. Also available at: http://korrekt.org/papers/KroetzschVrandecicVoelkelHaller_SemanticMediaWiki_2007.pdf.
30 Majchrzak A, Wagner C, Yates D. Corporate Wiki users: results of a survey. Proceedings of the 2006 International Symposium on Wikis. WikiSym'06. 2006 August 21–23. Odense, Denmark. 2006:99-104. Available at: http://www.wikisym.org/ws2006/proceedings/p99.pdf.
31 Welcome to Medpedia. San Francisco. Medpedia, Inc. 2007. Available at: http://www.medpedia.com. February 25, 2009.
32 Di Iorio A, Zacchiroli S. Constrained Wiki: an Oxymoron?. Proceedings of the 2006 International Symposium on Wikis. WikiSym '06. 2006 August 21–23. Odense, Denmark. 2006:89-98. Available at: http://www.wikisym.org/ws2006/proceedings/p89.pdf.
33 Wendling D. NIH Wiki Working Group. National Library of Medicine. Personal communication. 2008.
34 About Wikis: wiki-based work at NLM— white paper. Bethesda (MD). National Library of Medicine. 2008. Oct. 10.
35 Jackson J. Intellipedia suffers midlife crisis, Government Computer News. 2009. Feb. 19. Available at: http://www.gcn.com/Articles/2009/02/18/Intellipedia.aspx. March 3, 2009.
36 NIH enterprise architecture. Wiki Working Group final report. Bethesda (MD). National Institutes of Health. 2006. Jun. 1.
37 Campanini S, Castagna P, Tazzoli R. Platypus wiki: a semantic wiki wiki web. Ancona (Italy). Semantic Web Applications and Perspectives (SWAP). 2004. Available at: http://semanticweb.deit.univpm.it/swap2004/cameraready/castagna.pdf.