# Recommendations

## Is There a Place for Wikis in the AHRQ EPC Program?

There are a number of ways that wikis could enhance collaboration for the EPCs without adding undue burdens. The most easily implemented use for a wiki would be establishing Communities of Practice based on methodologies. The EPC Librarians' Working Group might be a good group to pilot such a project—a central repository for resources and search strategies could be very beneficial and information professionals tend to be more comfortable with online platforms than some other user groups. The ECRI Information Center began using an informal wiki for this purpose after researching wikis for this project.

“Homepages” for ongoing EPC projects would be another useful early implementation of wikis. Although wikis can foster new forms of online collaboration they can also serve the same purpose as other Web sites, making information available to users with access privileges through any Internet connection. Wiki access could be provided to all contributors to the project and serve as a hub for meeting minutes, project documents, and other materials without support from an IT department. Users could contribute to more collaborative areas of the wiki as they become more comfortable with the technology.

Using a wiki for report authoring and review is a tantalizing prospect. There are many benefits of having a centralized single version of a document that represents the entire document history, including input from various authors and reviewers. However, as was pointed out earlier in this report, wiki technology is not sufficiently developed yet for authoring and reviewing reports on this scale. If AHRQ chooses piloting a wiki for collaborative authoring and review, an EPC representative should contact Liccardi et al.14 to discuss the possibility of piloting the CAWS system, discussed in the “Collaborative Authoring” Section. Implementing wiki-based authoring and review would also require expert wiki users familiar with AHRQ processes to develop templates and training materials.

This white paper was partially authored using the PBwiki platform. PBwiki is a WYSIWG application and we did not add extensions to increase functionality. In many ways it was useful, including easy access to abstracted information from articles, easy dissemination amongst the workgroup, and universal access via the Internet. However, the flat structure did lead to some disorganization, which improved when tags were added to categorize the information. The wiki version of this white paper will differ in format to leverage the benefits of hyperlinks.

## Selecting a Wiki

If AHRQ does decide to incorporate wikis, the choice of wiki platform should be carefully considered. There are many issues associated with selecting a wiki and there is an ever-increasing variety of wikis to choose from. Questions that might be asked when selecting a wiki platform for authoring and review could include:

- Can you put a lock on a page so only one user can revise at a time?
- If you allow simultaneous editing how does the wiki handle conflicts?
- Does the platform allow internal comments?
- Does the platform distinguish between minor (e.g., spelling) and more substantive changes?
- Are the pages equally readable in both edit and reading modes?
- Can weights be assigned to input by different reviewers?
- How does it accommodate the massive amount of data generated in systematic reviews?
- Can the platform be customized for statistical analysis?

Additional elements for consideration are the system infrastructure requirements, the level of maintenance required by the system and cost. Identifying workflow and sociocultural elements should be part of the decisionmaking process as well. Lists of comparable specifications are provided in Appendix B. Sites such as WikiMatrix and the Wikipedia Comparison of Wiki Software page help potential users to evaluate wikis on multiple dimensions; WikiMatrix currently contains data on 118 wikis and lists MediaWiki, DokuWiki, PmWiki, TWiki, and PhpWiki as the most frequently compared wikis.

In 2006, the Office of the Chief IT Architect of the National Institutes of Health (NIH) convened a working group to investigate the best application of wikis for NIH enterprise. The group was charged with developing and issuing a Request for Information for wiki solutions, conducting market research analyses, examining Federal and agency-specific governance guidelines, determining wiki best practices, surveying the NIH population for current wiki use, and reviewing existing wiki sites within the government. Members of the working group were drawn from departments across NIH. The group's final report was published in June 2006.^36^ (See NIH_Wiki_Final_Report.pdf)

Despite concerns with the effects wikis might have on productivity and the potential degradation of the reliability of posted information, the group found that wikis foster and support collaboration within and across organizational groups in a wide range of situations. Some specific benefits were a broader sense of ownership and greater participation, wider access to content, and distribution of workload. This resulted in project completion with shortened timeframes and more efficient workflow. The ease of customization, agile and lightweight interfaces, and interactive and dynamic nature of the tools were noted as elements of this success.

The Working Group reported a number of issues relevant to AHRQ that remain unanswered:

- Should relationships be established between internal wikis? If so, how should these relationships be defined, implemented and maintained?
- Wikis should have determined and finite life cycles. Are there any archiving requirements or mandates?
- How should the Freedom of Information Act (FOIA) be interpreted in the context of a wiki?

Although the group did not recommend a specific technology, it did make recommendations for internal and external uses of wikis for the NIH enterprise, some of which are also applicable for AHRQ. These were:

- The wikis should be behind the agency firewall.
- The wikis should be accessible through AHRQ's Clinical Information Web site.
- The content should be indexed and searchable.
- A library of predetermined templates should be developed.

Before moving forward with a wiki project, AHRQ should investigate its current Web governance policies and identify personnel that could contribute to the wiki selection process. The EPCs also need to decide whether they wish to create a network of wikis within the umbrella of an enterprise wiki system or create a series of independent wikis which could be connected via hyperlinks. In either case, since several HHS agencies are using the commercial Confluence enterprise wiki, it would be useful to contact them to determine what informed their decision on this platform. It would also be advisable to determine whether HHS is planning standardization on a wiki platform.

This literature review reveals numerous ways in which wikis could enrich the EPC community and processes. The next step should be discussion of issues identified in this report amongst the broader EPC community with the goal of launching Community of Practice and project-specific wiki pilots.