# Project Overview

The Agency for Healthcare Research and Quality (AHRQ) is interested in leveraging new collaborative technologies to improve communications within and between various programs within its purview. To investigate some possibilities, the ECRI Institute Evidence-based Practice Center (EPC) was charged with examining the feasibility of using a wiki to support the collaborative development of evidence reports, technical briefs, and systematic reviews by AHRQ's EPCs. A wiki is “a type of Web page designed so that its content can be edited by anyone who accesses it, using a simplified markup language,” according to The Oxford English Dictionary. Wikis 1could serve multiple purposes in the workflow for EPCs. In addition to serving as a mechanism for reviewing draft reports, wikis could be used in earlier stages of topic refinement and report development, such as in the developmental phases of key questions, inclusion/exclusion criteria, and search strategies. The wiki could serve as a collaborative platform for general methods development and methodology-related discussions and potentially could facilitate submission of topic nominations by partner organizations and public stakeholders.

At AHRQ's request, this study explores access, governance, and policy issues related to using a wiki for peer review of reports, and its feasibility and potential in the longer term as a platform for report publication, updating, and dissemination. It also explains technical and operational considerations involved with different types of wikis and addresses other points of interest, such as issues of Section 508 compliance.

This project was researched in 2008. Several approaches were used to gather material for this study. Systematic searches were conducted of bibliographic databases, conference proceedings, and digital repositories to identify publications of interest. Searches of the Internet were also conducted to identify grey literature and sample wikis. A case report based on an interview with representatives of the Agence d'évaluation des technologies et des modes d'intervention en santé (AETMIS), the government agency in the Canadian province of Quebec responsible for Health Technology Assessment, is included in Appendix D to this report.

Finally, we make recommendations on using a wiki for review of systematic reviews and other report-development activities based on our research and our use of the PBwiki platform while authoring this report. This tool is now available as PBworks (www.pbworks.com).