# Potential Uses for Wikis at AHRQ

The initial scope of this task order focused on the feasibility of using wikis in the context of AHRQ systematic reviews. However, there are many ways in which the introduction of wikis could enrich communication and collaboration within the EPC community.

## EPC Community of Practice

A wiki could help foster an EPC community of practice (CoP). Communities of practice are “groups of people informally bound together by shared expertise and passion for a joint enterprise … people in communities of practice share their experiences and knowledge in free-flowing, creative ways that foster new approaches to problems.”6 Communities of practice differ from formal work groups, project teams, and informal networks in several ways. First, CoPs exist to benefit the members via knowledge exchange and exist as long as there is an interest in maintaining the group. Other collaborative groups exist to deliver a product or service, accomplish a task, or to collect and disseminate information related to a business or organizational goal. These groups may be formed by the organization and membership may be a job requirement. Wenger and Snyder6 note some organizational benefits that accrue when members participate in CoPs. These include new ways of driving strategy, creating new lines of business, quicker problem solving, transfer of best practices, professional skill development, and new methods of recruiting and retaining group members. The EPCs don't fit neatly into any of these categories—they are independent organizations that are bound together through their individual commitments to AHRQ. However, the members of the EPC teams do share interests in topic areas that transcend individual reports, such as methodology and disseminating research results that could serve as the basis of these CoPs.

## Central Hub for Methodology

The EPC program researches methodologies relevant to systematic review in addition to specific diseases, interventions, and diagnostic technologies. Providing access to methodology research in real time could provide valuable insight and cross-pollinate ideas between projects. This could easily serve as the core for an EPC CoP.

## Connecting Related Topic Areas

A wiki could also be a useful way of linking AHRQ research across multiple categories. EPC projects could be linked with Centers for Education and Research on Therapies (CERT) and Developing Evidence to Inform Decisions about Effectiveness (DEcIDE) projects in complementary subject areas. Portions of separate EPC reports on similar subject areas could also be linked—the first example to come to mind is genetic testing. This topic is currently of great interest, and there are published and ongoing reports in this area, some of which are interrelated—at least three or four EPCs have previously or are currently assigned to work on projects addressing different aspects of genetic testing. Creating a topic-related forum would allow researchers from these different EPCs to share their experiences and easily communicate their “lessons learned.”

## Individual Sites for Project Working Groups

### Example—Analytic Validity of Genetic and Laboratory Tests

Most EPC projects are collaborative efforts between the individual EPCs, AHRQ Task Order Officers, partner organizations, Key Informants, and Technical Experts. At present, collaborations are managed via e-mail, shared documents, shared Web conferencing (e.g., WebEx, LiveMeeting) and conference calls. Adding a wiki into this mix would simplify and reduce redundancy in these processes. However, collaborators will need to confirm that the application isn't blocked by their institutional firewalls at the onset of the project. The front page of the wiki would include a description of the project including background and context along with links to official documents such as the task order and to the other sections of the wiki. Other sections would represent different aspects of the project. For example, one section of the wiki would be focused on introducing team members, identifying their roles and areas of expertise, and specifying best methods of contact. Another would be dedicated to announcing events such as conference calls and stakeholder meetings and would lead the user to the minutes for these events. Detailed minutes or brief synopses linked to more detailed documents would be available from this page. This section would also provide content on meeting locations, hotels, travel, reservations, and other logistical matters. The technical section of the wiki would include content such as the key questions and analytic framework for the project, proposed search strategies and search reports, inclusion/exclusion criteria, and proposed statistical methods. Additional sections could be reserved for suggesting peer reviewers, reference lists, and evidence tables. Links could also be provided to TrialStat or other systematic review support sites.

The above examples are suggested internal uses of a wiki. Wiki may also be an efficient method of disseminating draft documents for public review. This could be accomplished by creating a separate section in the project wiki with less stringent access controls, or, by creating a separate wiki for the review stage and linking it to the project wiki. Other public uses could include topic solicitation and a structured feedback area seeking public input on more general areas such as best practices for disseminating reports, or determining how well the summary guides developed from the comparative effectiveness reviews are received by intended audiences.

## Collaborative Authoring

Wikis work well for collaborative activities such as brainstorming, planning, and reviewing, but there is less evidence how well they function as a platform for authoring complex reports.5,7-9 Wilder and Ferris wrote of their experience using a wiki to write about wikis. They note that “using a wiki to write a document destined for a linear publication was a futile exercise from the outset.”10 They found that working with hypertext in the flat wiki structure led them to forget elements necessary for traditionally published documents such as titles and abstracts. This may be a pitfall if a traditional approach is taken, however, there are alternatives to be explored.

One consideration is how many authors will be authoring the report and whether they will be working jointly, simultaneously, or sequentially. Noel and Robert comment on a number of approaches, including parallel writing, where authors work on their sections concurrently; sequential authoring, in which one author at a time works on a draft and passes the responsibility on; joint authoring, in which a group collaboratively authors a draft in real time; and a scribing approach, in which jointly created documents are entered into the wiki by a single author. They consider awareness, which they define as “an understanding of the activities of others which provides a context for your own activity” crucial for successful collaboration.11 Liccardi et al. discuss differences between group and individual authoring. They note that contributions from the different writers should be coherent together and that this requires an editor and enhanced functionality in software. They also found most users prefer parallel writing—either users work separately and occasionally upload their sections or write the entire sections separately and merge the sections with the document upon completion. These authors have developed the CoAuthoring Wiki-based System (CAWS) as a tool for writing professional papers.12-14 Like Noel et al., they note that “it is important for people collaboratively authoring a document to be informed about the changes that have been made to the document between versions, when new parts are added to the document and by whom. Being aware of these changes helps the users to better understand the evolution of the document, to more easily cooperate with others and avoid possible conflicts.” Problems with collaborative online authoring identified by these authors include:

- Communication degradation
- Misinterpretation of comments referring to specific sections
- Resolving conflicting suggestions for revision
- Poor tools for annotation
- Version tracking
- Update conflicts
- Awareness
  ○ personal
  ○ social
  ○ informal
  ○ group
  ○ workspace

The CAWS was designed to emulate face-to-face interaction and address the above problems. First, “instead of multiple pages the system comprises multiple document sections that form a complete document.” Each document would have a front page that provides authors with an informal update on current activity and events. This enhances what the authors call “informal” awareness. “Personal awareness” is addressed through providing each author with a user page and requesting that they update it periodically. Users would also be able to designate their “status”—this would indicate whether the author could be disturbed and provides “social” awareness. “Group awareness” is addressed through a page which includes users' roles, responsibilities, positions on issues and statements, and status related to assigned goals. In addition to these pages, administrative tools enhance author awareness by linking discussions to an annotation system. Comments can be color-coded by commenter or by the type of comment (e.g., suggestion, proposal, request for discussion) to provide visual cues to users. Users can also specify which revisions will trigger an automated notification for them.13 CAWS has been examined in two field studies involving undergraduates working on a group project and postgraduates collaboratively authoring a document. As a result of these studies, the authors plan to augment CAWS with an instant messaging system to provide more immediate communication. As of early 2009, this system is still under research.

## Review and Editing

A number of practical issues need to be determined by the EPC community before structuring a wiki for peer review.

- Should the draft be posted as a document or should pages be created for the sections? Uploading draft documents to a wiki site allows document review without distracting reviewers from the content with a new editing environment. Taking this approach turns the wiki into a convenient centralized method of disseminating information while retaining access to review tools such as tracking changes. Encouraging reviewers to make their comments using structured wiki templates would add another layer of usefulness to the wiki. However, reviewers could upload their completed review documents to the wiki as well. Alternatively, the report could be available as one or more wiki pages. This would allow reviewers to make comments directly in the document (much as they would do using “track changes”). This would centralize comments from multiple reviewers and simplify the comment integration process. Guidance for reviewers could be provided in a Frequently Asked Questions (FAQs) section. Either of these approaches could decrease the time needed for this part of the review process since the authors would become aware of the reviewer's comments as soon as they are posted.
- If the reports are made available as wiki pages, should the formatting mirror existing AHRQ reports or should a more flexible wiki structure be used? Currently, the Web version of a comparative effectiveness review consists of a single html page with intradocument links for navigation. This could easily be replicated in a wiki, but it might be unwieldy for reviewers. Wiki pages could be created to represent different sections of the report (e.g., methods, results, evidence tables). One of the advantages of “Web 2.0” approaches is giving users easy means of personalizing content. In the context of the wiki, this includes adding tags to pages. If the entire report is in a single page, appending tags wouldn't be as useful. Breaking the report into different pages allows users to apply tags more specifically.
- Should reviewers use templates? Providing semistructured templates encourages contributions to wikis. For peer review and discussion of EPC projects, structured templates based on current peer-review forms and checklists could be generated. This ensures that all reviewers consider the same elements and should at least mirror current instructions for peer reviewers. Authors should have input on specific questions for each project.
- How do you create and manage time-limited review periods? The review period could start once reviewers receive their access, and periodic alerts could be generated advising reviewers when comments are due. Edit access can be removed at the end of the review period. Using a wiki for review would provide more transparency into the review process and let the EPCs know when their reports were actively being reviewed.
- Would the reviewers be able to see each others' comments during the review process? Could this introduce bias? Would it be better to provide each reviewer with their own draft page that they can both edit and comment on? This would facilitate replies to individual reviewers, but merging could be difficult at the end. Should a general discussion page be created where reviewers can interact after they've completed their review?
- Since wikis can be continually revised, how do you know when the reviewers' comments are final? A checklist page for reviewer signoffs could be created. The reviewer would indicate on this page that his/her edits are “final,” and a date and timestamp would automatically be provided.
- Do responses to reviewer comments on the talk page constitute a sufficient response to reviewers or are more formal replies required? Currently, disposition of comments is handled through documents with tables that list the reviewer's comment and the resulting action of the EPC. Wiki pages could be formatted in multiple ways to enhance this process. The table format could be retained if desired, but both the comment and dispositions could be linked to the relevant section of the report (or reports if the draft version will remain available).

Wikis can be easily edited, but it is difficult to link a comment to a specific statement within the text. MediaWiki and PBwiki are two wiki platforms that were considered for this pilot project. PBwiki creates comments at the bottom of the page, and MediaWiki creates a separate tab (namespace) for discussions. Can a unique identifier be assigned to each sentence or segment to improve this process? How would this be maintained? One proposed solution is Purple Numbers. This is software that produces HTML documents that can be addressed at the paragraph level. The software automatically creates name anchors with static and hierarchical addresses at the beginning of each text node and by displaying these addresses as links at the end of each text node. Using this approach, reviewers could specifically reference the subject of their comment regardless of the comment location. Purple Tools are available for developers to incorporate Purple Numbers into their applications.15 Purple Numbers have been implemented as part of the government's COLAB Collaborative Work Environment.

What happens when multiple editors try to save an edit at the same time? Ignat et al. examined how MediaWiki handles concurrent saves and compares this with peer-to-peer approaches.16 They found that in this circumstance the user who submits the edits first wins and the others fail. Nonwinning users are presented with two versions of the page—the one they tried to publish and the now-current revision of the page. The author can then determine whether the desired edits are still required and, if so, paste them into the new revision. There is no automated merging—users manually combine the parallel modifications.

Wikis are continually in flux—how do you make sense out of revision histories? Viegas et al. used history flow visualizations to study cooperation and conflict between Wikipedia authors with the goal of determining whether page edits are significant or if there are recognizable trends and patterns.17 Their history flow visualization was designed to graphically show relationships between multiple document revisions. Contributors are each assigned a different color in the visualization, and the sections of revision lines are colored according to the original author. Sections that remained the same between consecutive versions are linked using shaded connections between corresponding segments on adjacent revision lines. The spacing of revision lines indicates the passage of time. The authors noted a number of patterns including what they termed “first user advantage” in which the original content on a page survives longer and experiences fewer modifications than later edits. They also noted that people tended to delete and insert text more frequently than moving text in an article. Many of the negative patterns noted in Wikipedia would not be relevant in the context of an inward-facing AHRQ wiki but would apply if an AHRQ wiki were open to the public and permitted anonymous contributions. These include different forms of vandalism, such as mass deletion of content and edit wars, in which two or more editors or groups alternate between versions of a page. These patterns should be taken into consideration when governance policies are established for a collaborative space.

Kittur et al. also address the issues of conflict and coordination in wikis, using Wikipedia as a specific example.18 They point out that conflict in online communities is complex and is associated with positive values as well as negative. These include resolving disagreements, establishing consensus, clarifying issues, and strengthening common values. However, conflict does lead to more indirect work, which they define as “excess work in the system that does not directly lead to new article content.” This includes discussion, user coordination, maintenance activities such as reverts to earlier revisions, and anti-vandalism.