# Introduction to Wikis

## What Is a Wiki?

“A wiki is to a typical Web site what a dialogue is to a monologue.”2

According to Ward Cunningham, the “father” of wikis, a wiki is the “simplest online database that could possibly work.” Wikis are server-based online content management systems that ease creating, editing, organizing, and storing information for any user with Internet access. Users may freely create and edit Web page content using any Web browser, although some wiki sites function best using specified browsers such as Microsoft's Internet Explorer and Mozilla Firefox. Wiki allows inexperienced users to create Web content without knowledge of markup and programming languages—wikis support hyperlinks and use simple text syntax for creating new pages and crosslinks between internal pages on the fly. Many wiki applications now embed WYSIWYG (what you see is what you get) capability to ease the process even further.

One of the key characteristics of a wiki is its initial flat structure. Pages are easily created and are connected to each other via hyperlinks. This results in more of a web of nodes than a hierarchical structure which allows users to easily customize the wiki to meet the needs of individuals and projects. This makes wiki unusual among group communication mechanisms in that it allows the organization of contributions to be edited in addition to the content itself.

Wiki is also a philosophy about how users should go about editing content in wiki platforms3 and working in a wiki requires users to shift their perceptions about documents and collaborative work. Wiki is generally considered part of Web 2.0. According to Choate,2 the “term [Web 2.0] was coined in an effort to capture what was different about companies that survived the Internet bust of early 2000, and those that did not. As such, Web 2.0 is not a set of web technologies per se, rather, it is a set of attributes shared by successful Internet companies.” These characteristics include user participation, geographic and organizational decentralization, use of links and hypertext (embedded links that transfer users to related content within or between documents/Web pages), and an emergent nature (e.g., the system arises out of the interactions of many contributors). In Web 2.0 applications such as wikis, emphasis is given to the dynamic nature of information. There is no final version of a document, just the current revision. This has an impact on the authoritativeness of published information. Users also need to shift their concept of authoring and ownership. As Guy notes, “The notion of ownership remains so deeply embedded in our society that many users still find it difficult to change things on another person's Web site.”4

Another key attribute of wikis is the revision history that is created for each page. This history captures the full version of each revision plus the time, the author, and the specific changes made in that revision. Reversion to any revision is possible. This differentiates wikis from other groupware in which only the changes are saved. Another difference between wikis and other content management systems is “that content is put in the wiki during the project, not after the fact.” This makes wikis more of an “active hub” rather than a “file cabinet.”5