# Government Wikis

## National Library of Medicine (NLM)

Dan Wendling, a member of the NIH Work Group, was interviewed by members of the ECRI Institute EPC in October 2008 to discuss the implementation of a wiki at NLM.33,34 NLM has launched a pilot wiki on a commercial enterprise wiki platform (Atlassian's Confluence) with access limited to staff only. Although the NLM team considered using the open-source MediaWiki platform, they eventually chose the commercial system because they believed it requires less behind-scenes processing, and they felt their use case would be better served using an enterprise system which could provide multiple spaces with different permissions for viewing, editing, adding, and deleting content. The goal of the wiki was enhanced idea sharing, marshalling and presenting facts, and providing word processing within a browser. The initial steps involved policy and standards development and creating user roles. The group decided on three levels of usage: readers, participants, and administrators. The pilot wiki “went live” in May 2008 with 20–30 different spaces. Eight hundred staff members have access to the wiki, but only 80 were specifically told of its existence. Within 6 months after the launch approximately 200 staff members have viewed pages, and there are approximately 30 active users. The initial launch did not include user training but, according to Wendling, they are now rethinking this approach and are considering physically gathering users for training sessions and providing more FAQs.

## NASA

The NASA wiki hosts the Federal Knowledge Management Working Group (KMWG) wiki, which brings together initiative-based and action groups within the Federal Government.

## COLAB

The Center for Intergovernmental Solutions is the “U.S. government organization whose primary mission is to bring public-sector leaders together to share information, knowledge, and experience in leveraging best-practices to improve services to citizens.” COLAB provides the workspace and tools for this endeavor. It is a collaborative work environment hosted by GSA Intergovernmental Solutions that includes a community portal, forum, and shared document repository as well as a community wiki. It currently hosts 30 intergovernmental communities of practice.

## Intellipedia

Intellipedia is a wiki for the U.S. government intelligence community and was originally hosted by the Central Intelligence Agency. It is now managed by the Office of the Director of National Intelligence. The pilot version of the wiki was announced to the intelligence community in April 2006 and is open to anyone with a government email account. It is used by analysts, working groups, and engineers within the intelligence community. This wiki is not open to public access; however, as of 2008, there have been more than 1.5 million edits submitted by more than 35,000 registered users.35