# Acknowledgments

We thank our Internal Reviewers, Paul Anderson, B.A.,Vivian H. Coates, M.B.A., Janice Kaczmarek, M.S., Evan LeGault, B.A., Karen Schoelles, M.D., S.M., and Jonathan Treadwell, Ph.D. at ECRI Institute, Plymouth Meeting, PA.