# Case Study: Community of Practice Based on a Wiki

The Agence d'évaluation des technologies et des modes d'intervention en santé (AETMIS), the Canadian government agency in the province of Quebec responsible for health services and technology assessment, decided to look into using a wiki to share information about their research projects about three years ago. Most researchers are on contract and are far-flung, working at home approximately three days a week. “We have developed a community of practice based on a wiki,” says Reiner Banken, M.D., Deputy Director of AETMIS. The wiki helps researchers and staff members think together about their shared interests and research in their community of practice.

Communities of practice are “groups of people who share a concern, a set of problems, or a passion about a topic, and who deepen their knowledge and expertise in this area by interacting on an ongoing basis”.6 A wiki provides a way to create, nurture and sustain an intellectual community of this nature without its members ever physically coming together by providing them with an asynchronous electronic meeting space.

For its meeting space, AETMIS chose TikiWiki, an open-source, Web-based application. According to the Open Source Initiative, “Open source is a development method for software that harnesses the power of distributed peer review and transparency of process.” (Available at: http://www.opensource.org/). Currently, TikiWiki is actively developed by a large international community, and “can be used to create all sorts of Web applications, sites, portals, knowledge base, intranets, and extranets.” (See the TikiWiki Fact Sheet, available at: http://info.tikiwiki.org/Fact+Sheet).

AETMIS uses TikiWiki as a wiki-based intranet/extranet. The agency found that this platform has the “great advantage of a very well developed system of permissions for accessing pages, and we are using this system to create collaborative workspace for researchers,” says Banken. AETMIS also uses TikiWiki as the platform for the INAHTA/HTAi glossary [The International Network of Agencies for Health Technology Assessment/Health Technology Assessment International (HTAi)]. The agency used TikiWiki as a project management and information sharing tool for organizing the HTAi 2008 meeting. Currently AETMIS is working with TikiWiki developers on bibliographic database tools and mind-mapping applications. As TikiWiki is open source, all developments become part of future releases.

The AETMIS staff learned to use TikiWiki by pairing up staff members and having the more computer-savvy staff (regardless of age) teach the staff members who were less experienced with using computers to use the wiki. This process took time, but eventually staff members adapted to the wiki. Initially, AETMIS began with an intranet, but now the agency has an extranet so that external researchers can also participate in the community of practice, and exchange information and ideas. Now researchers are beginning to collaborate on writing.

“The fundamental elements of a Community of Practice are: a domain of knowledge, a community of people and shared practices. Wikis can be seen as a supporting technology for a Community of Practice: they enable users to discuss around a page representing a concept, they adapt to situations in which knowledge changes quickly, and they do not impose any extra overhead on those who want to contribute.”37

Going forward, Banken says, “We plan to use the wiki to interact with stakeholders on research projects. Our reports should make sense to all of the stakeholders involved. It's very difficult to involve all of our stakeholders in the process. The wiki is another tools that we can use making our work transparent to them, helping them understand what we do, and involving them in our work.”

Screen shots and additional information are available at Wiki at AETMIS.

[This section authored by Jeanette de Richemond, Ph.D. Candidate, Communication, Library and Information Science, and Media Studies at Rutgers University]

## Listing of Patterns and Abstracted Case Studies from WikiPatterns5

Figure D-1 Selected WikiPatterns

Source: www.wikipatterns.com/display/wikipatterns/Wikipatterns

Figure shows four lists that are selected WikiPatterns. These four WikiPatterns are: People Patterns, People Anti-Patterns, Adoption Patterns, and Adoption-Anti-Patterns.

Table D-1 Abstracted case studies from WikiPatterns

Organization | Reason for Using a Wiki | Type of Wiki | How is it being used? | Outcomes & Changes
LeapFrog Interview was conducted 3 months before widespread corporate rollout www.leapfrog.com pp. 17-23 | Info management system for product ideas, tracking concept development & improve collaboration | Commercial enterprise wiki (sounds like Confluence) Private | Gave it a human name— Emma Emma Support Emma Users Group Separate wiki spaces:; - personal; - project; - organizational group; - site-wide FAQ system; - collective knowledgebase; - site framework; Tools that have evolved:; - “About” boxes for each space; - Source code repository; - dashboards; - employee blogs; - innovation spaces; Not the end application for all information | More unity—tears down walls between functional groups working on the same project emphasis shifted from presentation aesthetics to information creation and distribution Emma has entered corporate lexicon increased ease of information access and transparency
Johns Hopkins University www.jhu.edu pp. 37-39 | Creating new student information system. Needed to communicate with project participants and stakeholders while reducing the volume of email. | Commercial enterprise wiki Private | Knowledgebase Document repository Employee blogs Departmental intranets Task force collaboration | Increased transparency Increased trust between project members and stakeholders Ideas are posting ideas and quickly receive comments, elaborations, invalidations, etc.
Sun Microsystems http://wikis.sun.com pp. 61-62 | Content sharing and collaboration | Readable by anyone—edit access for anyone with a Sun online account who has requested and been granted permission. Employees have global write access, outside users only have access to the pages that they've requested access to. | Collaborative creation of documents | Pages have been created for a variety of work and social-related topics.
Red Ant www.redant.com.au pp. 75-79 | Organization uses a central edit model. flexible communication both within company and with clients | Commercial enterprise wiki | Documenting meeting notes Client access to designs & prototypes Links to staging versions Present feedback and stats analysis in real-time Create filtered views of information Summary - WIP page | Stronger communication internally and externally Centralized data saves time Empowers team members
Center for Scholarly Technology - USC Jude Higdon pp. 81-85 | Intra- and inter-class communications | Enterprise wiki | Pilot expanded to 40 instructor-led projects involving more than 1,000 students Grad students in master of public policy program conducted research on insights into redeveloping urban areas devastated by natural disasters. Wiki was used in redesign ideas for 9th Ward in New Orleans Collectively generated knowledgebase on the history of the evolution debates Managing multisemester collaborative projects Platform for collaborative writing assignments | Increased instructor interest in creating nontraditional writing and collaboration assignments. Only 1 of the 40 projects ended early
JavaPolis Conference & Community (Belgium Java Users Group BeJUG) www.javapolis.com pp. 101-102 | Planning tool for large conference. Allows companies to update their own partner page, speakers to add or edit bios and abstracts, and updating the conference schedule and program. | Self-hosted JAVA wiki using Resin Web server and MySQL database | Conference Web site Schedule of events, information on speakers, partners, sponsors & news | Overcame initial skepticism. More community collaboration in voting, comments, and content updates
Chordiant Software Jeff Calado, Release Engineering Manager pp. 103-105 | Centralize information and enhance access | Self-hosted commercial enterprise wiki | Space for each team and each project Posting meeting notes and specs Created email account for the wiki and added it to the project email group. Emails are automatically downloaded to the project site for archiving. | Centralization of project information Expectation that people will take relevant information from their heads and share it on the wiki. Decreased learning curve for new employees and increased consistency in the training process. Improved knowledge and skills of broader team
Kerrydale Street Celtic Football Club www.kerrydalestreeet.com fan club for a Scottish football team pp. 117-119 | Co-op fans to build the “ultimate” fan site | Free consumer-oriented hosted wiki service | Comprehensive guide to Celtic FC | Rapid site growth Site returned in first page of Google searches for the team
National Constitution Center Constitution Day Education Nonprofit organization Tom Hillhouse pp. 127-128 | Community-oriented content management system. | Commercial enterprise wiki | Permission-based Structured metadata Template based design | Task distribution Empower users
Creative Digital Industries Mapping Project - Queensland University of Technology http://wiki.cci.edu.au/display/NMP pp. 129-139 | Cutting through bureaucracy which was functional for large groups but not for small mapping project. Enhance collaboration for cross-disciplinary global project Goals: Encourage & facilitate discussion and agreement regarding approaches to taxonomies and strategies Forum for sharing info Harness knowledge and “willingness to participate” Asynchronous communication | Confluence enterprise wiki | Established 4 levels of access: Anonymous public - can view entire site but cannot edit or comment Self-enrolled researchers and practitioners - see, edit, & comment on most parts of site. Add & edit pages and forums. Project partners, contractors & consultants - same as researchers but can also access the project administration area Project Administrator - manages user logins, authority levels, page and global access Still in first generation of usage. Plans for second generation: Infrastructure for delivering eResearch services Citation management Networking “sandboxes” | Benefits projects with a high coordination requirement (such as RFPs) within a relatively short time frame. Allows researchers to take direct control of the publishing and communication with their collaborators and community with a minimum of distraction