# Recommended Reading

Albers A, Sauter C, Meboldt M, et al. Semantic wikis in knowledge management for multidisciplinary product development. Katalinic B, editor. Annal of DAAAM for 2007 & Proceedings of the 18th International DAAAM Symposium. Vienna, Austria. DAAAM International. 2007:5-6.
Andersson E, Rosenström P, Söhrman S. Introducing the wiki concept to a knowledge organisation: a case study at AstraZeneca: examining the important aspects of a wiki's initial phase. Goteborg, Sweden. Department of Informatics, IT University of Goteborg. 2007.
Aviero D, Mendes J, Tribolet J. Organizational Modeling with a Semantic Wiki. Proceedings of the 2008 ACM symposium on Applied Computing. Symposium on Applied Computing. March 16-20, 2008. Fortaleza, Ceara, Brazil. Association of Computing Machinery. 2008:592-3.
Baumeister J, Reutelshoefer J, Puppe F. Know WE: community-based knowledge capture with knowledge wikis. K-CAP '07: Proceedings of the 4th International Conference on Knowledge Capture. New York. Association for Computing Machinery, Inc. 2007:189-190. [doi: 10.1145/1298406.1298448].
Bell S. Wikis as legitimate research sources. Online. Nov-Dec. 2008;32(6):34-7.
Buzzi M, Leporini. Is wikipedia usable for the blind?. Proceedings of the 2008 international cross-disciplinary conference on Web accessibility (W4A). W4A2008. April 21-22, 2008. Beijing, China. Association for Computing Machinery, Inc. 2008:15-22.
Canadian Health Services Research Foundation (CHSRF). Innovation through collaboration: working together for an evidence-informed health system. Report of the 8th annual invitational workshop, Canadian Health Services Research Foundation Vancouver, British Columbia. March 21-22, 2006. Ottawa (ON). Canadian Health Services Research Foundation. 2006. Mar.
Chan CM, Bhandar M, Oh LB, et al. Recognition and participation in a virtual community. Proceedings of the 37th annual Hawaii international conference on system sciences. 2004 Jan 5-8. Big Island (HI). Los Alamitos (CA). IEEE. 2004:1-10.
Chau T, Maurer F. A Case Study of Wiki-based Experience Repository at a Medium-sized Software Company. Proceedings of the 3rd international conference on Knowledge capture. International Conference On Knowledge Capture. October 2-5, 2005. Banff, Alberta, Canada. Association of Computing Machinery, Inc. 2005:185-6.
Choo CW, Bergeron P, Detlor B, et al. Information culture and information use: an exploratory study of three organizations. J Am Soc Inf Sci Technol. 2008;59(5):792-804.
Choo CW, Detlor B, Turnbull D. Web Work: Information seeking and knowledge management on the world wide web. Dordrecht, Netherlands. Kluwer Academic Publishers. 2000. Social learning cycle (Boisot) and organizational knowing. Aavailable at: http://choo.fis.utoronto.ca/Kluwer/KOOL.html.
Choo CW, Detlor B, Turnbull D. Web Work: Information seeking and knowledge management on the world wide web. Dordrecht, Netherlands. Kluwer Academic Publishers. 2000. The intranet and the knowledge processes of Nonaka & Takeuchi. Available at: http://choo.fis.utoronto.ca/Kluwer/Nonaka.IN.html.
Choo CW. Information seeking in organizations: epistemic contexts and contests, Info Res. 2007;12(2). Available at: http://informationr.net/ir/12-2/paper298.html.
Choo CW. The social use of information in organizational groups. (preprint). Huizing A, de Vries EJ, editors. Information management: Setting the scene. Oxford (UK). Elsevier Science. 2007;1. Available at: http://choo.fis.utoronto.ca/FIS/SSHRC/GKW/ICIMchapter.pdf.
Coyle JE Jr. Wikis in the college classroom: a comparative study of online and face-to-face group collaboration at a private liberal arts university. Kent (OH). Kent State University. 2007. May. Available at: http://www.educ.kent.edu/OAA/documents/COYLE.pdf.
Cunningham W. Design principles of wiki: how can so little do so much?. Proceedings of the 2006 International Symposium on Wikis. International Symposium on Wikis. August 21-23, 2006. Odense, Denmark. Association for Computing Machinery, Inc. 2006:13-14. [doi: 10.1145/1149453.1149459].
de Pedro Puente X. New method using Wikis and forums to evaluate individual contributions in cooperative work while promoting experiential learning: results from preliminary experience. WikiSym'07. 2007 Oct 21-23. Montréal, Québec, Canada. Ottawa (ON). National Research Council of Canada. 2007:87-92.
Deitering AM, Bridgewater R. Stop reinventing the wheel: using Wikis for professional knowledge sharing. Corvallis (OR). Oregon State University.
Dekel U. A framework for studying the use of Wikis in knowledge work using client-side access data. Proceedings of the 2007 International Symposium of Wikis. WikiSym '07. 2007 Oct 21-23. Montreal, Quebec. Association for Computing Machinery, Inc. 2007:25-30.
Désilets A, Paquet S, Vinson NG. Are wikis usable?. Proceedings of the 2005 international symposium on Wikis . WikiSym '05. October 16–18, 2004. San Diego (CA). Association for Computing Machinery. 2005:3-15.
Désilets A, Paquet S, Vinson NG. Are Wikis usable?. WikiSym'05. 2004 Oct 16-18. San Diego (CA). Ottawa (ON). National Research Council of Canada. 2005:3-15.
Di Iorio A, Fabbri M, Presutti V, et al. Automatic deployment of semantic wikis: a prototype. Italy. Department of Computer Science, University of Bologna. Available at: http://ftp.informatik.rwth-aachen.de/Publications/CEUR-WS/Vol-206/paper18.pdf.
Di Iorio A, Zacchiroli S. Constrained Wiki: an Oxymoron?. Proceedings of the 2006 international symposium on Wikis. WikiSym '06. August 21-23, 2006. Odense, Denmark. Association for Computing Machinery. 2006:89-98.
Di Iorio A, Vitali F. From the writable web to global editability. Proceedings of the sixteenth ACM conference on hypertext and hypermedia. Conference on Hypertext and Hypermedia. September 6-9, 2005. Salzburg, Austria. Association of Computing Machinery, Inc. 2005:35-45. [doi: 10.1145/1083356.1083365].
Ding X, Danis C, Erickson T, et al. Visualizing an enterprise wiki. CHI '07 extended abstracts on Human factors in computing systems. Conference on human factors in computing systems. April 28–May 3, 2007. San Jose (CA). Association for Computing Machinery, Inc. 2007:2189-94.
Ducasse S, Renggli L, Wuyts R. SmallWiki—a meta-described collaborative content management system. WikiSym'05;. 2004 Oct 16-18. San Diego (CA). Ottawa (ON). National Research Council of Canada. 2005:75-82.
EbM in quality management and operational medicine. 8th Annual Meeting of the German network e. V. Evidence-based medicine. 2007 Mar 22-24. Berlin (DE). Duesseldorf, Cologne, DE. German Medical Science. 2007. Mar. 15. Available at: http://www.egms.de/en/meetings/ebm2007/07ebm006.shtml.
Eto K, Takabayashi S, Masui T. Qwik Web: integrating mailing list and WikiWikiWeb for group communication. WikiSym'05. 2004 Oct 16-18. San Diego (CA). Ottawa (ON). National Research Council of Canada. 2005:17-23.
Fountain RM. Conceptual enhancement via textural plurality: a pedagogical Wiki bow towards collaborative structuration. Proceedings of the 2007 International Symposium on Wikis. International Symposium on Wikis. October 21-25, 2007. Montreal, Quebec. Association for Computing Machinery, Inc. 2007:43-46. [doi: 10.1145/1296951.1296956].
Fuchs-Kittowski F, Köhler A. Wiki communities in the context of work processes. WikiSym'05. 2004 Oct 16-18. San Diego (CA). Ottawa (ON). National Research Council of Canada. 2005:33-9.
Gallant LM, Boone GM, Heap A. Five heuristics for designing and evaluating Web-based communities, First Monday. Mar. 2007;12(3). Available at: http://www.firstmonday.org/issues/issue12_3/gallant/index.html.
Government Web managers conference and best practice awards. [slide set]. Washington (DC). Web Content Managers Advisory Council. 2008. May.
Guy M. Wiki or won't he? A tale of public sector wikis, Ariadne. Oct. 2006;(49):1-11. online. Available at: http://www.ariadne.ac.uk/issue49/guy.
Haake A, Lukosch S, Schummer T. Wiki-templates. Adding structure support to wikis on demand. Proceedings of the 2005 international symposium on Wikis. WikiSym '05. October 16-18, 2005. San Diego (CA). Association for Computing Machinery. 41-51.
Hammond R. Party lines, wikis, and project management. Online. Sep-Oct. 2007;31(5):30-3.
Han HS, Kim H, Han SG. Analyzing the effectiveness of collaborative condition monitoring using adaptive measure. WSEAS Trans Info Sci Appl. Aug. 2006;3(8):1495-1500.
Hansen DL. Knowledge sharing, maintenance, and use in online support communities. CHI '06 extended abstracts on Human factors in computing systems. Conference on Human Factors in Computing System. April 22-27, 2006. Montreal, Quebec. Association for Computing Machinery, Inc. 2006. [doi: 10.1145/1125451.1125780].
Hasan H, Meloche JA, Pfaff CC, et al. Beyond ubiquity: co-creating corporate knowledge with a wiki. Proceedings of the international conference on mobile ubiquitous computing, systems, services and technologies. Washington (DC). IEEE Computer Society. 2007:35-40.
Hasan H, Pfaff CC. The Wiki: an environment to revolutionise employees' interaction with corporate knowledge. Proceedings of the 20th conference of the computer-human interaction special interest group (CHISIG) of Australia on Computer-human interaction: design: activities, artefacts and environments. November 20-24, 2006. Sydney, Australia. Association of Computing Machinery, Inc. 2006:377-80.
Hester A. Innovating with organizational wikis: factors facilitating adoption and diffusion of an effective collaborative knowledge management system. Proceedings of the 2008 ACM SIGMIS CPR conference on Computer personnel doctoral consortium and research. SIGMIS-CPR '08. April 3–5, 2008. Charlottesville (VA). Association for Computing Machinery. 2008:161-3.
Hill MD, Gaudiot JL, Hall M, et al. A wiki for discussing and promoting best practices in research. Commun Acm. Sep. 2006;49(9):63-4.
Hinze-Hoare V. Computer supported collaborative research. United Kingdom. University of Southampton. Available at: http://arxiv.org/ftp/arxiv/papers/0711/0711.2760.pdf.
HohmanSaiedian.html.ted software projects, Crosstalk. Aug. 2008:1-8. Available at: http://www.stsc.hill.af.mil/crosstalk/2008/08/0808.
Huss JW 3rd, Orozco C, Goodale J, et al. A gene wiki for community annotation of gene function. PLoS Biol. Jul. 8. 2008;6(7):e175. [pmid: 18613750].
Ignat CL, Oster G, Molli P, et al. A comparison of optimistic approaches to collaborative editing of wiki pages. Cedex (FR). Loria.
Johnson KR, Freeman SR, Dellavalle RP. Wikis: the application of Web 2.0. Arch Dermatol. Aug. 2007;143(8):1065-6. [pmid: 17709668].
Katalinic B, editor. Annal of DAAAM for 2007 & proceedings of the 18th international DAAAM symposium. Vienna, Austria. DAAAM International. 2007:5-6.
Kittur A, Suh B, Pendleton BA, et al. He Says, She Says: Conflict and Coordination in Wikipedia. Proceedings of the SIGCHI conference on Human factors in computing systems. Conference on Human Factors in Computing Systems. April 28-May 3, 2007. San Jose (CA). Association for Computing Machinery, Inc. 2007:453-462. Also available at: http://www-users.cs.umn.edu/…/2007-Wikipedia-coordination-PARC-CHI2007.pdf.
Lee FS, Vogel D, Limayem M. Virtual community informatics: what we know and what we need to know. Proceedings of the 35th Hawaii International Conference on System Sciences. Big Island (HI). Los Alamitos (CA). IEEE. 2002. Available at: http://csdl2.computer.org/comp/proceedings/hicss/2002/1435/08/14350214b.pdf.
Liccardi I, Davis HC, White S. CAWS: a wiki system to improve workspace awareness to advance effectiveness of co-authoring activities. CHI ‘07 extended abstracts on human factors in computing systems. Conference on human factors in computing systems. April 28 - May 3, 2007. San Jose (CA). Association for Computing Machinery, Inc. 2007:2555-2560. [doi: 10.1145/1240866.1241040].
Liccardi I, Davis HC, White S. CAWS: an awareness based wiki system to improve team collaboration. Eighth international conference on advanced learning technologies. 2008 Jul 1-5. IEEE Explore. 2008:265-7.
Liccardi I. CAWS: improving users' awareness in collaborative authoring activities. Group ‘07 Doctoral Consortium papers. November 4–7, 2007. Sanibel Island (FL). Association for Computing Machinery. 2007. Article No. 6.
Long SA. Exploring the wiki world: the new face of collaboration. New Library World. 2006;107(1222/1223):157-159. [doi: 10.1108/03074800610654934].
Mader S. Wikipatterns. Indianapolis (IN). Wiley Publishing, Inc. 2008.
Majchrzak A, Wagner C, Yates D. Corporate Wiki users: results of a survey. WikiSym'06. 2006 Aug 21-23. Odense, Denmark. Ottawa (ON). National Research Council of Canada. 2006:99-104.
Moore TD, Serva MA. Understanding member motivation for contributing to different types of virtual communities: a proposed framework. Proceedings of the 2007 ACM SIGMIS CPR conference on computer personnel research: The global information technology workforce. SIGMIS-CPR ‘07. April 19-21, 2007. St. Louis (MO). Association for Computing Machinery. 2007:153-158.
NIH Enterprise Architecture Office. Wiki Working Group final report. Bethesda (MD). National Institutes of Health. 2006. Jun. 1.
NIH model for web governance and support. NIH Enterprise Architecture Office. 2007. Aug. 31.
O'Flahavan L. Not all wikis are encyclopedias: other types of wikis and how your company could use one. [slide set]. Silver Spring (MD). e-Write.
Oxford English Dictionary Online. [internet]. New York (NY). Oxford University Press. 2007. Mar. Available at: http://dictionary.oed.com. December 12, 2008.
Pentzold C, Seidenglanz S. Foucault@Wiki first steps towards a conceptual framework for the analysis of wiki discourses. Proceedings of the 2006 international symposium on Wikis. WikiSym ‘06. August 21–23, 2006. Odense, Denmark. Association for Computing Machinery. 2006:59-68. Available at: http://www.wikisym.org/ws2006/proceedings/p59.pdf.
Priedhorsky T, Chen J, Lam S, et al. Creating, destroying, and restoring value in wikipedia. Proceedings of the 2007 International ACM conference on Conference on supporting group work. Conference on Supporting Group Work. November 4-7, 2007. Sanibel Island (FL). Association for Computing Machinery Inc. 2007:259-268. [doi: 10.1145/1316624.1316663.].
Proceedings of the 2007 international symposium on Wikis. 2007 Oct 21-25. Montreal, Quebec, Canada. Ottawa (ON). National Research Council of Canada. 2007.
Ramos M, Piper PS. Letting the grass grow: grassroots information on blogs and wikis. Reference Serv Rev. 2006;34(4):570-4.
Reinhold S. WikiTrails: augmenting Wiki structure for collaborative, interdisciplinary learning. Proceedings of the 2006 international symposium on Wikis . WikiSym ‘06. August 21–23, 2006. Odense, Denmark. Association for Computing Machinery. 2006:47-57.
Ricciato F. Some remarks to recent papers on traffic analysis: or the case for public Wiki-like platforms for commenting published papers. ACM SIGCOMM Comp Commun Rev. Jul. 2006;36(3):99-102.
Roth C. Viable Wikis: struggle for life in the wikisphere. WikiSym'07. 2007 Oct 21-23. Montreal, Quebec, Canada. Ottawa (ON). National Research Council of Canada. 2007:119-24.
Sabel M. Structuring wiki revision history. Proceedings of the 2007 international symposium on Wikis. WikiSym ‘07. October 21-23, 2007. Montreal, Quebec, Canada. 2007:125-129. Available at: http://ws2007.wikisym.org/space/SabelPaper.
Schoberth T, Preece J, Heinzl A. Online communities: a longitudinal analysis of communication activities. Proceedings of the 36th annual Hawaii international conference on system sciences. 2003 Jan 6-9. Big Island (HI). Los Alamitos (CA). IEEE. 2003:1-10. Available at: http://www.ifsm.umbc.edu/~preece/paper/9 HICSSNOCD06v2.pdf (http://www.ifsm.umbc.edu/~preece/paper/9_HICSSNOCD06v2.pdf).
Semantic Wikipedia. 2007. Aug. 31. Available at: http://korrekt.org/papers/KroetzschVrandecicVoelkelHaller_SemanticMediaWiki_2007.pdf.
Shanks B. WikiGateway: a library for interoperability and accelerated wiki development. Proceedings of the 2005 international symposium on Wikis . WikiSym ‘05. October 16-18, 2005. San Diego (CA). Association for Computing Machinery. 2005:53-66.
Snowden D. Complex knowledge. [slide set]. First Gurteen Knowledge Conference. London (UK). IBM UK Ltd. Jun. 1. 2003:42. Also available: http://www.gurteen.com/gurteen/gurteen.nsf/id/snowden-downloads/$file/2003%2006%20Gurteen%20Knowledge%20Conference.ppt.
Souzis A. A Building a semantic wiki. IEEE Intel Syst. Sep-Oct. 2005;20(5):87-92.
Suh B, Chi EH, Kittur A, et al. Lifting the Veil: Improving Accountability and Social Transparency in Wikipedia with WikiDashboard. Proceeding of the twenty-sixth annual SIGCHI conference on Human factors in computing systems . CHI ‘08 Conference on Human Factors in Computing Systems. April 5-10, 2008. Florence, Italy. Association of Computing Machinery Inc. 2008:1037-40.
Suvinen H, Saariluoma P. User psychological problems in a wiki-based knowledge sharing portal. Proceedings of the 2008 third international conference on internet and web applications and services. Washington (DC). IEEE Computer Society. 2008:552-7.
Tapscott D, Williams AD. Wikinomics: how mass collaboration changes everything. expanded ed. New York (NY). Penguin Group. 2008.
The wiki principle. Economist. Apr. 22. 2006;379:Survey 14-Survey 15.
Think tank: determinants of information use outcomes. Bethesda (MD). National Library of Medicine. 2008. Oct. 10.
Think tank: if you build it, will they come? A survey on cultural determinants of information systems use. Bethesda (MD). National Library of Medicine. 2008. Oct. 16.
Tolksdorf R, Bontas Simperl EP. Towards Wikis as semantic hypermedia. WikiSym 2006. 2006 Aug 21–23. Odense, Denmark. Ottawa (ON). National Research Council of Canada. 2006:79-88.
Tonkin E. Making the case for a Wiki, Ariadne. Jan. 2005;(42):1-8. online. Available at: http://www.ariadne.ac.uk/issue42/tonkin/.
Vazey M, Richards D. A case classification conclusion 3Cs approach to knowledge acquisition: applying a classification logic wiki to the problem solving process. Int J Knowl Manage. Jan-Mar. 2006;2(1):72-88.
Viegas FB, Watenberg M, Dave K. Studying Cooperation and Conflict between Authors with history flow Visualizations. Conference on Human Factors in Computing Systems. Proceedings of the SIGCHI conference on Human factors in computing systems. April 24–29, 2004. Vienna, Austria. Association of Computing Machinery Inc. 2004:575-82.
Volkel M, Krotzsch M, Vrandecic D, et al. Semantic Wikipedia. Proceedings of the 15th international conference on World Wide Web. International World Wide Web Conference. May 23–26, 2006. Edinburgh, Scotland. Association of Computing Machinery, Inc. 2006:585-594.
Voss J. Workshop on wikipedia research. WikiSym'06. 2006 Aug 21–23. Odense, Denmark. Ottawa (ON). National Research Council of Canada. 2006:127.
Wagner C, Cheung KS, Ip RF, et al. Building semantic webs for e-government with Wiki technology. Elect Gov. 2006;3(1):36-55. [doi: 10.1504/EG.2006.008491.].
Wagner C. Breaking the knowledge acquisition bottleneck through conversational knowledge management. Info Res Manage J. Jan–Mar. 2006;19(14). Abstract.
Web Government Advisory Council. Tools for Government Web Managers. Unknown. Sept. 9. 2008:1-3. Available at: http://www.usa.gov/webcontent/resources/tools.shtml.
Weiss S, Urso P, Molli P. Wooki: a P2P wiki-based collaborative writing tool. Villers-Lès-Nancy (France). Institut National de Recherche en informatique et en automatique. 2007. Jun. 25.
Wendling D. Wiki theory and practice bibliography. Bethesda (MD). National Library of Medicine. 2008. Sep. 4.
Wiebrands C. Collaboration and communication via WIKI: the experience of Curtin University Library and Information Service. Western Australia. Curtin University of Technology Library. 2006. Also available at: http://eprints.rclis.org/archive/00007481/.
Wiki work-out: RoboHelp2Wiki. Bethesda (MD). National Library of Medicine. 2008. Oct. 17.
Wilder H, Ferris SP. Using a wiki to write about wikis. J Electron Pub. 2007;10(2).
Witte R, Gitzinger T. Connecting Wikis and natural language processing systems. WikiSym'07. 2007 Oct 21-23. Montreal, Quebec, Canada. Ottawa (ON). National Research Council of Canada. 2007:165-76.
Wu H, Zubair M, Maly K. Collaborative classification of growing collections with evolving facets. Proceedings of the 18th Conference on Hypertext and Hypermedia. Conference on Hypertext and Hypermedia. September 10-12, 2007. Manchester (UK). Norfolk (VA). Association for Computing Machinery Inc. 2007:167-70. [doi: 10.1145/1286240.1286289.].