# Elements That Can Be Compared Using WikiMatrix

- General Features
  ○ Author
  ○ URL
  ○ License Cost/ Fee
  ○ Intended Audience
- Security/Anti-Spam
  ○ Page Permissions
  ○ ACL
  ○ Host Blocking
  ○ Mail Encryption
  ○ nofollow
  ○ Blacklist
  ○ CAPTCHA
  ○ Delayed Indexing
- Development/Support
  ○ Commercial Support
  ○ Issue Tracker
  ○ Mailing List
  ○ Support Forum
  ○ IRC Channel
- Common Features
  ○ Preview
  ○ Minor Changes
  ○ Change Summary
  ○ Page History
  ○ Page Revisions
  ○ Revision Diffs
  ○ Page Index
  ○ Plugin System
- Special Features
  ○ Unicode Support
  ○ Right-to-Left Support
  ○ Interface Languages
  ○ Email notification
  ○ Comments
  ○ Categories
  ○ Namespaces
  ○ Page Redirection
  ○ Conflict Handling
  ○ Search
  ○ Structured Data
- Links
  ○ CamelCase
  ○ Freelinks
  ○ Backlinks
  ○ InterWiki
  ○ SisterWiki
  ○ Image Links
  ○ Windows Shares
  ○ Page Redirects
- Syntax Features
  ○ HTML Tags
  ○ Math formulas
  ○ Tables
  ○ CREOLE support
  ○ Markdown Support
  ○ Textile Support
  ○ BBCode Support
  ○ Emoticon Images
  ○ Syntax Highlighting
  ○ Footnotes
  ○ Quoting
  ○ Internal Comments
  ○ Custom styles
  ○ FAQ Tags
  ○ Scripting
  ○ Content Includes
  ○ Feed Aggregation
- Usability
  ○ Section Editing
  ○ Page Templates
  ○ Double-Click Edit
  ○ Toolbar
  ○ WYSIWYG Editing
  ○ Access Keys
  ○ Auto Signature
- Statistics
  ○ Recent Changes
  ○ Wanted Pages
  ○ Orphaned Pages
  ○ Most/Least Popular
  ○ Recent Visitors
  ○ Analysis
- Output
  ○ HTML
  ○ CSS Stylesheets
  ○ Printer Friendly
  ○ Mobile Friendly
  ○ Themes & Skins
  ○ RSS Feeds
  ○ ATOM Feeds
  ○ Abbreviations
  ○ Auto-TOC
  ○ Raw Export
  ○ HTML Export
  ○ XML export
  ○ PDF Export
- Media and Files
  ○ File Attachments
  ○ Media Revisions
  ○ Embedded Flash
  ○ Embedded Video
  ○ Image Editing
  ○ SVG Editing
  ○ MindMap Editing
  ○ Media Search
- Extras
  ○ Calendar
  ○ Image Galleries
  ○ Forums
  ○ Blogs
  ○ Ticket System