# Appendixes

Appendix A Requirements Checklist for Government Web Managers

Appendix B Elements That Can Be Compared Using WikiMatrix

Appendix C Recommended Reading

Appendix D Case Study: Community of Practice Based on a Wiki