# Steering Committee

Donna M. Dryden

University of Alberta EPC

Edmonton, Alberta, Canada

Lisa Hartling

University of Alberta EPC

Edmonton, Alberta, Canada

David Moher

University of Ottawa EPC

Ottawa, Ontario, Canada

P. Lina Santaguida

McMaster EPC

Hamilton, Ontario, Canada

Paul Shekelle

Southern California/RAND EPC

Santa Monica, CA