# Results

## Overview

The results are presented according to the tools we examined: Risk of Bias (ROB) tool for randomized controlled trials (RCTs) and Newcastle-Ottawa Scale (NOS) for cohort studies. Within each group we present a description of the reviewers involved in performing assessments, a description of the sample of studies assessed, and the results of the reliability and validity analyses, respectively.

## Risk of Bias and Randomized Controlled Trials

### Description of Reviewers

Twelve reviewers from the University of Alberta EPC and the University of Ottawa EPC assessed the RCTs using the ROB tool. These individuals had varying levels of relevant training, experience with systematic reviews in general, and experience with EPC work specifically. The length of time they had worked with their respective EPC ranged from 9 months to 10 years. Ten of the 12 reviewers had formal training in systematic reviews (i.e., they had taken a university course or attended a Cochrane workshop in systematic reviews). Three of the reviewers had a doctoral degree in epidemiology or health/clinical sciences; eight reviewers had a master's degree in epidemiology/public health, health/clinical sciences, or math/statistics; and one reviewer had an undergraduate degree in health sciences.

For the subset of 30 RCTs, two reviewers from each of the four EPCs were involved in applying the ROB tool and reaching consensus for each study. The reviewers had the following backgrounds: PhD (n=4), MD (n=1), PhD students with completed master's degrees (n=2), MD and master's degree (n=1), and master's degree (n=1). The length of time they had worked with an EPC ranged from 2 to 10 years. Six reviewers had formal training in systematic reviews.

### Description of Randomized Controlled Trials

We included 154 RCTs (Appendix A). Details of the trials overall and by risk of bias assessments are provided in Appendix G.

The majority of trials were published in specialty medical journals (87.7 percent). The median impact factor of the journal was 2.9 (interquartile range [IQR] 1.8, 5.1), and the mean number of authors was 7 (standard deviation 3.3). The countries represented most frequently were the United States (31.8 percent), Italy (8.4 percent), and the United Kingdom (8.4 percent). The majority of trials were performed in a single center (74 percent). Approximately 70 percent of trials declared a funding source: industry (27.3 percent) and government (26.0 percent) sources were most frequent.

The design of most trials was parallel (81.8 percent), efficacy/superiority (84.4 percent) with individuals as the unit of randomization (95.5 percent). Just over half of the trials examined drug interventions (53.3 percent), with behavioral/psychological (11.0 percent) and surgical (11.7 percent) interventions commonly represented. Only 35.7 percent of the trials were placebo-controlled. The median sample size was 63 (IQR 39, 123).

A wide range of diagnostic categories was represented (Appendix G). These were classified into: aging; cancer research; circulatory and respiratory health; gender and health; genetics; health services and policy research; human development, child and youth health; infection and immunity; musculoskeletal health and arthritis; neurosciences, mental health, and addiction; nutrition, metabolism, and diabetes; and population and public health. The most frequently represented categories were circulatory and respiratory health (18.2 percent), nutrition, metabolism, and diabetes (17.5 percent), and musculoskeletal health and arthritis (14.9 percent). The primary outcomes were objective in 48.1 percent of trials and subjective in 51.9 percent. Source of outcome assessment was primarily by clinician (35.1 percent), laboratory measure (23.4 percent), or self-report (23.4 percent).

The vast majority of trials had overall risk of bias assessments of high (46.8 percent) or unclear (52.6 percent) with only one trial assessed as low risk of bias (0.7 percent). Table 3 provides details on the risk of bias assessments for the individual domains. The domains that were most frequently rated as low risk of bias were sequence generation (54.6 percent), missing outcome data (63.6 percent), and selective reporting (77.3 percent). The remaining domains were most frequently assessed as unclear: allocation concealment (77.3 percent), blinding (48.7 percent), and “other sources of bias” (55.8 percent). These results should be interpreted with caution given the low level of agreement between reviewers (see section below).

Table 3 Risk of bias assessments by domain^*^ (N=124)

Domain | Risk of Bias Assessments – n (%)
| High | Unclear | Low
Sequence generation | 0 (0.0) | 70 (45.5) | 84 (54.6)
Allocation concealment | 2 (1.3) | 119 (77.3) | 33 (21.4)
Blinding | 21 (13.6) | 75 (48.7) | 58 (37.7)
Incomplete data | 29 (18.8) | 27 (17.5) | 98 (63.6)
Selective reporting | 16 (10.4) | 19 (12.3) | 119 (77.3)
Other sources of bias | 33 (21.4) | 86 (55.8) | 35 (22.7)
Overall risk of bias^†^ | 72 (46.8) | 81 (52.6) | 1 (0.7)

* The risk of bias assessments presented here are based on consensus between two reviewers.

† Items considered in “overall risk of bias” included design-specific risks of bias; early stopping for benefit; severe baseline imbalances; inappropriate influence of funders (Appendix B).

We explored study-level variables and their association with domain-specific and overall risk of bias (Table 4). Sequence generation was influenced by the nature of the outcome (objective outcomes showed higher risk of bias, p=0.01) and study design (parallel showed lower risk of bias, p=0.02). Allocation concealment was also influenced by the nature of the outcome with objective outcomes having higher risk of bias (p=0.0007). Blinding was influenced by nature of the intervention with pharmaceutical interventions having lower risk of bias (p=0.01). No variables were associated with risk of bias for incomplete data reporting. Selective outcome reporting was associated with the nature of the intervention (surgical trials showed higher risk of bias, p=0.002) and funding (industry support had higher risk of bias, p=0.04). “Other sources of bias” was associated with funding, with industry funding showing higher risk of bias (p<0.0001). Finally, overall risk of bias was also associated with funding, with industry funding showing higher risk of bias (p<0.0001). Of note, “other sources of bias” incorporates several considerations including “inappropriate influence of the study sponsor” (i.e., the extent and nature of involvement of the study sponsor and whether this would likely lead to biased results, Appendix B) which is different from source of funding (i.e., whether the study was funded by industry).

Table 4 Study-level variables and association with risk of bias

Domain | Study-Level Variable | Interpretation | P-value
Sequence generation | Nature of the outcome | Objective outcomes had higher RoB | 0.01
Allocation concealment | Nature of the outcome | Objective outcomes had higher RoB | 0.0007
Blinding | Nature of the intervention | Pharmaceutical interventions had lower RoB | 0.01
Selective reporting | Nature of the intervention | Surgical trials had higher RoB | 0.002
| Source of funding | Industry funding had higher RoB | <0.0001
Overall risk of bias^†^ | Source of funding | Industry funding had higher RoB | <0.001

RoB = risk of bias

† Items considered in “overall risk of bias” included design-specific risks of bias; early stopping for benefit; severe baseline imbalances; inappropriate influence of funders (Appendix B).

### Inter-rater Reliability

Inter-rater reliability for the RCTs is presented by domain in Table 5. Sequence generation had the highest level of agreement which was considered substantial. Reliability for the remaining domains was considered fair, with confidence intervals ranging from slight to moderate. The 3×3 tables from which the kappa statistics were derived are presented in Appendix H.

Table 5 Inter-rater reliability on risk of bias assessments, by domain (N=124)

Domain | Agreement, Weighted κ (95% CI) | Interpretation46
Sequence generation | 0.79 (0.70, 0.88) | Substantial
Allocation concealment | 0.24 (0.05, 0.43) | Fair
Blinding | 0.33 (0.17, 0.49) | Fair
Incomplete data | 0.34 (0.17, 0.52) | Fair
Selective reporting | 0.27 (0.06, 049) | Fair
Other sources of bias | 0.24 (0.06, 0.41) | Fair
Overall risk of bias | 0.21 (0.05, 0.37) | Fair

We assessed whether important study-level variables influenced inter-rater reliability (Table 6, Appendix I). These analyses include many comparisons and should be considered exploratory. They are meant to identify specific areas where more guidance in applying the tool may be helpful.

Table 6 Inter-rater reliability on risk of bias assessments, by domain and study-level variable^*^

Variable | Risk of Bias Domain, κ (Interpretation)^†^
| SG | AC | Blinding | Incomplete Outcome Data | SOR | Other
Overall | 0.79 (Su) | 0.24 (F) | 0.33 (F) | 0.34 (F) | 0.27 (F) | 0.24 (F)
Nature of intervention
Pharmacological | 0.82 (AP) | 0.26 (F) | 0.33 (F) | 0.36 (F) | 0.12 (Sl) | 0.38 (F)
Nonpharmacological | 0.77 (Su) | 0.24 (F) | 0.37 (F) | 0.26 (F) | 0.36 (F) | -0.06 (P)
p-value | 0.57 | 0.94 | 0.79 | 0.61 | 0.25 | 0.02
Nature of outcome
Objective | 0.71 (Su) | 0.22 (F) | 0.54 (M) | 0.33 (F) | 0.41 (M) | 0.09 (Sl)
Subjective | 0.88 (AP) | 0.27 (F) | 0.18 (Sl) | 0.32 (F) | 0.07 (Sl) | 0.45 (M)
p-value | 0.09 | 0.81 | 0.02 | 0.93 | 0.09 | 0.04
Study design
Parallel | 0.78 (Su) | 0.32 (F) | 0.27 (F) | 0.32 (F) | 0.21 (F) | 0.23 (F)
Other | 0.88 (AP) | -0.07 (P) | 0.77 (Su) | 0.34 (F) | 0.46 (M) | 0.30 (F)
p-value | 0.47 | 0.0002 | 0.0004 | 0.94 | 0.26 | 0.75
Trial hypothesis
Efficacy/superiority | 0.79 (Su) | 0.24 (Sl) | 0.33 (F) | 0.32 (F) | 0.38 (F) | 0.25 (F)
Other | 0.81 (AP) | 0.29 (F) | 0.44 (M) | 0.33 (F) | -0.31 (P) | 0.31 (F)
p-value | 0.92 | 0.83 | 0.64 | 0.97 | <0.0001 | 0.79
Funding
Industry | 0.63 (M) | -0.10 (P) | 0.52 (M) | 0.42 (M) | 0.51 (M) | 0.39 (F)
No industry | 0.85 (AP) | 0.38 (F) | 0.28 (F) | 0.29 (F) | 0.13 (Sl) | 0.21 (F)
p-value | 0.10 | 0.03 | 0.21 | 0.50 | 0.09 | 0.34

* Confidence intervals for all estimates are presented in Appendix I.

† AP=almost perfect, Su=substantial, M=moderate, F=fair, Sl=slight, P=poor;

AC = allocation concealment; SG = sequence generation; SOR = selective outcome reporting

Assessments for sequence generation and incomplete outcome data were not influenced by any variable. For allocation concealment, inter-rater agreement was better for trials with parallel versus other designs (e.g., crossover, factorial), and for those without industry funding versus those with industry funding. In terms of blinding, inter-rater agreement was better for objective versus subjective outcomes, and trials with other versus parallel designs. For selective outcome reporting, inter-rater agreement was greater for trials with hypotheses of efficacy/superiority versus others (e.g., equivalence, noninferiority). For “other sources of bias,” inter-rater agreement was better for trials examining pharmacological versus nonpharmacological interventions and subjective versus objective outcomes.

### Inter-consensus Reliability

A random sample of 30 studies was selected to compare consensus assessments across pairs of reviewers from the four participating EPCs. The results of the inter-EPC reliability are detailed in Table 7. There was moderate agreement for sequence generation, fair agreement for allocation concealment and “other sources of bias,” and slight agreement for the remaining domains and overall risk of bias with confidence intervals ranging from poor to fair. The 3×3 tables from which the kappa statistics were derived are presented in Appendix H.

Table 7 Inter-rater reliability between pairs of reviewers on risk of bias assessments across 4 EPCs (N=30)

Domain | Agreement κ (95% CI) | Interpretation46
Sequence generation | 0.60 (0.40, 0.79) | Moderate
Allocation concealment | 0.37 (0.19, 0.55) | Fair
Blinding | 0.09 (-0.07, 0.24) | Slight
Incomplete data | 0.05 (-0.10, 0.20) | Slight
Selective reporting | 0.08 (-0.09, 0.26) | Slight
Other sources of bias | 0.27 (0.11, 0.42) | Fair
Overall risk of bias | 0.10 (-0.10, 0.31) | Slight

As a post hoc exercise, we reviewed the disagreements to identify whether they stemmed primarily from reviewers identifying different information in the study reports, or from different interpretation of the criteria. In general, reviewers identified similar information for the domains of sequence generation, allocation concealment, blinding, selective outcome reporting, and “other sources of bias;” however, their judgments for risk of bias based on the same information varied. For incomplete outcome data and for assessing baseline imbalances within “other sources of bias,” reviewers often based their assessments on different information that they extracted from the study. Examples of these are provided in Table 8 below with more details and examples in Appendix J.

Table 8 Examples of sources of disagreement for the Risk of Bias tool

Domain | Case Description | Source of Disagreement
Sequence generation | All four EPCs noted block randomization – 2 interpreted as low RoB; 2 interpreted as unclear RoB | Interpretation of the criteria
Allocation concealment | All four EPCs found the description of ‘sealed envelopes’ – 1 low; 2 unclear; 1 high RoB | Interpretation of the criteria
Blinding | Study was described as ‘double-blind’, and had an objective outcome – 2 interpreted as low and 2 as unclear RoB | Interpretation of the criteria
| All four EPCs found the same description (open-label, blinded outcome assessor) – 2 low; 1 unclear; 1 high RoB | Interpretation of the criteria
Incomplete data | Two EPCs found complete followup (low RoB); two found insufficient information to judge (unclear RoB) | Assessment based on different information identified from study report
| One EPC stated that drop-outs were imbalanced between groups and followup was <90% (high RoB); one stated that followup was <90% (high RoB); one was unclear on validity of stated reasons for drop-outs (unclear RoB); one used 85% followup as the threshold (low RoB) | Interpretation of the criteria
Selective reporting | Two EPCs found no evidence of selective outcome reporting (low); two found outcomes not reported in the results section (1 unclear; 1 high) | Different information and interpretation of criteria
Other sources of bias | All four EPCs addressed the potential conflict of interest regarding industry involvement – 2 unclear; 2 high RoB | Interpretation of the criteria
| Two EPCs addressed baseline imbalances (unclear); two considered baseline characteristics to be balanced (low) | Interpretation of the criteria

### Validity

Figures 1 to 7 show the effect estimates for studies categorized as high, unclear, and low risk of bias. No statistically significant differences were found in effect sizes (ES) across the risk of bias categories for the six individual domains or overall risk of bias. There was no impact when controlling for study-level factors (i.e., no statistically significant differences were found).

Figure 1 Sequence generation (Meta-regression p=0.10)

Figure 1 depicts a number line of sequence generation with a meta regression p value of point one.

Figure 2 Allocation concealment (Meta-regression p=0.10)

Figure 2 depicts allocation concealment with in parenthesis meta regression with a p value of zero point one close parenthesis.

Figure 3 Blinding (Meta-regression p=0.31)

Figure 3 depicts blinding with in parenthesis meta regression with a p value of zero point three one close parenthesis.

Figure 4 Incomplete outcome data (Meta-regression p=0.16)

Figure 4 depicts incomplete outcome data with in parenthesis meta regression with a p value of zero point one six close parenthesis.

Figure 5 Selective outcome reporting (Meta-regression p=0.46)

Figure 5 depicts selective outcome reporting with in parenthesis meta regression with a p value of zero point four six close parenthesis.

Figure 6 Other sources of bias (Meta-regression p=0.74)

Figure 6 depicts other sources of bias with in parenthesis meta regression with a p value of zero point four six close parenthesis.

Figure 7 Overall risk of bias (Meta-regression p=0.98)

Figure 7 depicts overall risk of bias with in parenthesis meta regression with a p value of zero point nine eight close parenthesis.

## Newcastle-Ottawa Scale and Cohort Studies

### Description of Reviewers

Sixteen reviewers from the University of Alberta EPC and the University of Ottawa EPC assessed the studies using the NOS. Individuals had varying levels of relevant training, experience with systematic reviews in general, and experience with EPC work specifically. The length of time they had worked with their respective EPC ranged from 4 months to 10 years. Thirteen reviewers had formal training in systematic reviews. Four reviewers had a doctoral degree; 10 reviewers had a master's degree; 1 reviewer had a medical degree and master's degree; and 1 reviewer had an undergraduate degree.

### Description of Sample

The cohort studies were taken from eight meta-analyses which are described in Table 9. Further details are available in Appendix F.

Table 9 Description of meta-analyses of cohort studies included in sample

Topic Area (See Appendix F for Citations) | Source | Number of Studies Included in Our Sample
Breastfeeding and asthma | EPC report | 10
Impaired glucose tolerance and diabetes mellitus | EPC report | 17
Cardiac resynchronization therapy and all-cause mortality | EPC report | 11
Drug-resistant tuberculosis and positive treatment outcome | Medline | 13
Statins and mortality from severe infections and sepsis | Medline | 20
Red meat intake and prostate cancer | Medline | 15
Overweight and obesity and preterm birth before 37 weeks | Medline | 38
Antenatal depression and preterm birth | Medline | 20

### Inter-rater Reliability

Inter-rater reliability for the 131 cohort studies is presented by domain in Table 10. The item “was the followup long enough for the outcome to occur” had the highest level of agreement which was considered substantial. Reliability was moderate for both ascertainment of exposure and ascertainment of outcome. Reliability was fair for representativeness of the cohort, and slight for comparability of cohorts and adequacy of followup of cohorts. Selection of the non-exposed cohort and demonstration that the outcome was not present at the outset of the study had poor reliability. Reliability for the overall score (total number of stars) was fair.

Table 10 Inter-rater reliability on NOS assessments, by domain

Domain | Agreement κ^*^ (95% CI) | Interpretation46
Representativeness of the exposed cohort | 0.23 (0.09, 0.41) | Fair
Selection of the non-exposed cohort | -0.03 (-0.06, 0.00) | Poor
Ascertainment of exposure | 0.43 (0.25, 0.61) | Moderate
Demonstration that the outcome was not present at outset of study | -0.06 (-0.20, 0.07) | Poor
Comparability | 0.18 (-0.12, 0.47) | Slight
Assessment of outcome | 0.49 (0.28, 0.70) | Moderate
Length of followup sufficient | 0.68 (0.47, 0.89) | Substantial
Adequacy of participant followup | 0.29 (0.12, 0.46) | Fair
Total stars | 0.29^*^ (0.10, 0.47) | Fair

* We used a weighted kappa for the total score as it assumes some ordinality in the assessment; other kappas are not weighted, i.e., Cohen's kappa.

In general, the reviewers found the tool difficult to use. They found the decision rules to be vague, even with the additional information we provided as part of this study. General points that arose were whether to assess each study based on the individual report, or as it related to the systematic review question. For instance, if the systematic review question was specific to a particular population, then the study population may be representative. However, the study population may not be representative of the average population in the community (first NOS item). Similarly, reviewers wanted specific guidance on whether to base assessments on the information contained in the specific study report, or whether to incorporate information from other reports of the same study. For instance, in numerous cases study authors would refer to another publication for details on the sample or specific methods. Studies could be unnecessarily penalized if they did not incorporate other pertinent information that was available from other reports.

Reviewers found it difficult to determine the difference between some of the response options. For example, two of the response options for item 1 regarding the exposed cohort are “truly” versus “somewhat” representative. Some reviewers questioned whether this distinction was important, as both responses garnered a star for that item, hence there was no difference in the final score. Also with respect to the first item, reviewers were uncertain regarding what makes a population “selected.” Some interpreted this to include populations with unequal representation of a certain group (e.g., 90 percent males, all patients had organ transplant) while others relied on the methods of selection (e.g., volunteers, select group such as nurses). Likewise, reviewers questioned the difference between the categories “structured interview” and “written self-report” for ascertainment of exposure. For example, researchers may use structured, validated surveys or questionnaires (e.g., SF-36) but these are completed independently by the study participant.

Reviewers were uncertain on how to assess the item on comparability. Some studies discussed testing different confounders in their models, but only included the confounders that showed a significant difference in the final model. Reviewers were unsure whether to indicate that the study controlled for that confounder.

Reviewers questioned what some domains actually measured. For instance, whether the selection domain assesses bias in how the participants were selected, or whether it is intended to assess the applicability of the study population to the population in general. Further, some concerns were raised that the response categories within a domain measured different constructs.

Reviewers would have liked “unclear” or “no description” options for some items, in particular for the last item on “adequacy of followup of cohorts.” They identified an additional problem with the response categories for this item. The second option is either a small number lost or description provided of those lost. The third option is a larger number lost and no description of those lost. However, there is no response option that includes a larger number lost and a description is provided (e.g., that indicates there was no imbalance between groups).

### Validity

We found no association between individual NOS items or overall NOS score and effect estimates (Table 11).

Table 11 Results of meta-meta-analysis of quality items and measures of association

Domain | ROR | 95% CI
Representativeness of the exposed cohort | 1.01 | 0.85, 1.20
Selection of the non-exposed cohort | 1.83 | 0.92, 3.64
Ascertainment of exposure | 1.13 | 0.93, 1.37
Demonstration that the outcome was not present at outset of study | 0.72 | 0.49, 1.07
Comparability | 0.86 | 0.56, 1.31
Assessment of outcome | 1.04 | 0.79, 1.38
Length of followup adequate | 0.84 | 0.55, 1.27
Adequacy of participant followup | 0.99 | 0.91, 1.08

ROR (ratios of odds ratios) that are greater than 1 indicate that studies of higher quality had larger effect sizes on average than studies with lower quality. The RORs presented were pooled across all of the eight meta-analyses that provided data for that quality item; if all studies in a meta-analysis were rated the same for a quality item, that meta-analysis did not contribute to that ROR.