# References

1 Cochrane Handbook for Systematic Reviews of Interventions. Higgins PT, Green S, editors. 2009. 5.0.2 [updated September 2009]. Available from: http://cochrane-handbook.org.
2 Bastian H, Glasziou P, Chalmers I. Seventy-five trials and eleven systematic reviews a day: how will we ever keep up?. PLoS Med. 2010;7(9):e1000326. [pmid: 20877712].
3 Moher D, Jadad AR, Nichol G, et al. Assessing the quality of randomized controlled trials: an annotated bibliography of scales and checklists. Control Clin Trials. 1995;16(1):62-73. [pmid: 7743790].
4 Juni P, Witschi A, Bloch R, et al. The hazards of scoring the quality of clinical trials for meta-analysis. JAMA. 1999;282(11):1054-60. [pmid: 10493204].
5 West S, King V, Carey TS, et al. Systems to rate the strength of scientific evidence. Evid Rep Technol Assess (Summ). 2002;(47):1-11. [pmid: 11979732].
6 Olivo SA, Macedo LG, Gadotti IC, et al. Scales to assess the quality of randomized controlled trials: a systematic review. Phys Ther. 2008;88(2):156-75. [pmid: 18073267].
7 Kjaergard LL, Villumsen J, Gluud C. Reported methodologic quality and discrepancies between large and small randomized trials in meta-analyses. Ann Intern Med. 2001;135(11):982-9. [pmid: 11730399].
8 Siersma V, ls-Nielsen B, Chen W, et al. Multivariable modelling for meta-epidemiological assessment of the association between trial quality and treatment effects estimated in randomized clinical trials. Stat Med. 2007;26(14):2745-58. [pmid: 17117373].
9 Sanderson S, Tatt ID, Higgins JP. Tools for assessing quality and susceptibility to bias in observational studies in epidemiology: a systematic review and annotated bibliography. Int J Epidemiol. 2007;36(3):666-76. [pmid: 17470488].
10 Deeks JJ, Dinnes J, D'Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7(27):iii-173. [pmid: 14499048].
11 Cochrane Handbook for Systematic Reviews of Interventions. Higgins PT, Green S, editors. 2011. (5.1.0. [updated March 2011]). Available from: http://cochrane-handbook.org.
12 Moher D, Pham B, Jones A, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352(9128):609-13. [pmid: 9746022].
13 Schulz KF, Chalmers I, Hayes RJ, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273(5):408-12. [pmid: 7823387].
14 Als-Nielsen B, Gluud LL, Gluud C. Methodological quality and treatment effects in randomised trials: a review of six empirical studies. 12th Cochrane Colloquium 2004. Oct 2-6. Ottawa, Ontario, Canada.
15 Balk EM, Bonis PA, Moskowitz H, et al. Correlation of quality measures with estimates of treatment effect in meta-analyses of randomized controlled trials. JAMA. 2002;287(22):2973-82. [pmid: 12052127].
16 Egger M, Juni P, Bartlett C, et al. How important are comprehensive literature searches and the assessment of trial quality in systematic reviews? Empirical study. Health Technol Assess. 2003;7(1):1-76. [pmid: 12583822].
17 Pildal J, Hrobjartsson A, Jorgensen KJ, et al. Impact of allocation concealment on conclusions drawn from meta-analyses of randomized trials. Int J Epidemiol. 2007;36(4):847-57. [pmid: 17517809].
18 Savovic J. The association of three bias domains with treatment effect estimates in randomised control trials: combined analysis of meta-epidemiological studies. Z Evid Fortbild Qual Gesundhwes. 2008;102:29-30.
19 Wood L, Egger M, Gluud LL, et al. Empirical evidence of bias in treatment effect estimates in controlled trials with different interventions and outcomes: meta-epidemiological study. BMJ. 2008;336(7644):601-5. [pmid: 18316340].
20 Melander H, hlqvist-Rastad J, Meijer G, et al. Evidence b(i)ased medicine--selective reporting from studies sponsored by pharmaceutical industry: review of studies in new drug applications. BMJ. 2003;326(7400):1171-3. [pmid: 12775615].
21 Porta N, Bonet C, Cobo E. Discordance between reported intention-to-treat and per protocol analyses. J Clin Epidemiol. 2007;60(7):663-9. [pmid: 17573981].
22 Tierney JF, Stewart LA. Investigating patient exclusion bias in meta-analysis. Int J Epidemiol. 2005;34(1):79-87. [pmid: 15561753].
23 Abraha I, Duca PG, Montedori A. Empirical evidence of bias: modified intention to treat analysis of randomised trials affects estimates of intervention efficacy. Z Evid Fortbild Qual Gesundhwes. 2008;102(Suppl VI):9.
24 Nuesch E, Trelle S, Reichenbach S, et al. Empirical evidence of attrition bias in meta-analyses of randomized controlled trials. Z Evid Fortbild Qual Gesundhwes. 2008;102:9.
25 Chan AW, Hrobjartsson A, Haahr MT, et al. Empirical evidence for selective reporting of outcomes in randomized trials: comparison of protocols to published articles. JAMA. 2004;291(20):2457-65. [pmid: 15161896].
26 Chan AW, Krleza-Jeric K, Schmid I, et al. Outcome reporting bias in randomized trials funded by the Canadian Institutes of Health Research. CMAJ. 2004;171(7):735-40. [pmid: 15451835].
27 Chan AW, Altman DG. Identifying outcome reporting bias in randomised trials on PubMed: review of publications and survey of authors. BMJ. 2005;330(7494):753. [pmid: 15681569].
28 Dwan K, Altman DG, Arnaiz JA, et al. Systematic review of the empirical evidence of study publication bias and outcome reporting bias. PLoS ONE. 2008;3(8):e3081. [pmid: 18769481].
29 Hahn S, Williamson PR, Hutton JL. Investigation of within-study selective reporting in clinical research: follow-up of applications submitted to a local research ethics committee. J Eval Clin Pract. 2002;8(3):353-9. [pmid: 12164983].
30 Von Elm E, Rollin A, Blumle A, et al. Selective reporting of outcomes of drug trials? Comparison of study proptocols and published articles. XIV Cochrane Colloquium 2006. October 23-26. Dublin, Ireland.
31 Bassler D, Ferreira-Gonzalez I, Briel M, et al. Systematic reviewers neglect bias that results from trials stopped early for benefit. J Clin Epidemiol. 2007;60(9):869-73. [pmid: 17689802].
32 Montori VM, Devereaux PJ, Adhikari NK, et al. Randomized trials stopped early for benefit: a systematic review. JAMA. 2005;294(17):2203-9. [pmid: 16264162].
33 Bekelman JE, Li Y, Gross CP. Scope and impact of financial conflicts of interest in biomedical research: a systematic review. JAMA. 2003;289(4):454-65. [pmid: 12533125].
34 Lexchin J, Bero LA, Djulbegovic B, et al. Pharmaceutical industry sponsorship and research outcome and quality: systematic review. BMJ. 2003;326(7400):1167-70. [pmid: 12775614].
35 Sismondo S. Pharmaceutical company funding and its consequences: a qualitative systematic review. Contemp Clin Trials. 2008;29(2):109-13. [pmid: 17919992].
36 Gotzsche PC, Hrobjartsson A, Johansen HK, et al. Constraints on publication rights in industry-initiated clinical trials. JAMA. 2006;295(14):1645-6. [pmid: 16609085].
37 Savovic J, Harris R, The Brando Collaborators. [O16-61] The association of three bias domains with treatment effect estimates in randomised control trials: combined analysis of meta-epidemiological studies. [Abstract]. Cochrane Colloquium Abstracts Journal. 2008.
38 Hartling L, Ospina M, Liang Y, et al. Risk of bias versus quality assessment of randomised controlled trials: cross sectional study. BMJ. 2009;339:b4012. [pmid: 19841007].
39 Hartling L, Bond K, Vandermeer B, et al. Applying the risk of bias tool in a systematic review of combination long-acting beta-agonists and inhaled corticosteroids for persistent asthma. PLoS ONE. 2011;6(2):e17242. [pmid: 21390219].
40 Wells G, Shea B, O'Connell J, Robertson J, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analysis. [Website]. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. 2011. Available from: URL: http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp (http://www.orhi.ca/programs/clinical_epidemiology/oxford.asp).
41 Wells G, Shea B, O'Connell J, Robertson J, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analysis. [Abstract]. 3^rd^ Symposium on Systematic Reviews: Beyond the Basics. July 3–5. Oxford. 2000.
42 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. 1998;52(6):377-84. [pmid: 9764259].
43 Wells G, Brodsky L, O'Connell D, Robertson J, et al. Evaluation of the Newcastle-Ottawa Scale (NOS): an assessment tool for evaluating the quality of non-randomized studies. [Abstract]. XI Cochrane Colloquium: Evidence, Health Care and Culture. Oct 26–31. Barcelona, Spain. 2003.
44 Hopewell S, Dutton S, Yu LM, et al. The quality of reports of randomised trials in 2000 and 2006: comparative study of articles indexed in PubMed. BMJ. 2010;340:c723. [pmid: 20332510].
45 Liebetrau A. Measures of association. Newbury Park, CA. Sage Publications. 1983.
46 Landis JR, Koch GG. The measurement of observer agreement for categorical data. Biometrics. 1977;33(1):159-74. [pmid: 843571].
47 Fleiss JL, Levin BA, Paik MC. Statistical methods for rates and proportions. 3 ed. Wiley. 2003.
48 Rosenthal R. Parametric measures of effect size. Cooper H, Hedges LV, editors. The Handbook of Research Synthesis. New York. Russel Sage Foundation. 1994.
49 Chinn S. A simple method for converting an odds ratio to effect size for use in meta-analysis. Stat Med. 2000;19(22):3127-31. [pmid: 11113947].
50 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
51 Ip S, Chung M, Raman G, et al. Breastfeeding and maternal and infant health outcomes in developed countries. Evid Rep Technol Assess (Full Rep). 2007;(153):1-186.
52 McAlister FA, Ezekowitz J, Dryden DM, et al. Cardiac resynchronization therapy and implantable cardiac defibrillators in left ventricular systolic dysfunction. Evid Rep Technol Assess (Full Rep). 2007;(152):1-199. [pmid: 17764218].
53 Santaguida PL, Balion C, Hunt D, et al. Diagnosis, prognosis, and treatment of impaired glucose tolerance and impaired fasting glucose. Evid Rep Technol Assess. 2005;(128):1-11.
54 Furukawa TA, Watanabe N, Omori IM, et al. Association between unreported outcomes and effect size estimates in Cochrane meta-analyses. JAMA. 2007;297(5):468-70. [pmid: 17284696].
55 Buxton AE, Lee KL, Fisher JD, et al. A randomized study of the prevention of sudden death in patients with coronary artery disease. Multicenter Unsustained Tachycardia Trial Investigators. N Engl J Med. 1999;341(25):1882-90. [pmid: 10601507].
56 Sanchez JM, Katsiyiannis WT, Gage BF, et al. Implantable cardioverter-defibrillator therapy improves long-term survival in patients with unexplained syncope, cardiomyopathy, and a negative electrophysiologic study. Heart Rhythm. 2005;2(4):367-73. [pmid: 15851337].
57 Frost FJ, Petersen H, Tollestrup K, et al. Influenza and COPD mortality protection as pleiotropic, dose-dependent effects of statins. Chest. 2007;131(4):1006-12. [pmid: 17426203].
58 Tseng MY, Hutchinson PJ, Czosnyka M, et al. Effects of acute pravastatin treatment on intensity of rescue therapy, length of inpatient stay, and 6-month outcome in patients after aneurysmal subarachnoid hemorrhage. Stroke. 2007;38(5):1545-50. [pmid: 17413047].
59 Wisner KL, Sit DK, Hanusa BH, et al. Major depression and antidepressant treatment: impact on pregnancy and neonatal outcomes. Am J Psychiatry. 2009;166(5):557-66. [pmid: 19289451].
60 Suri R, Altshuler L, Hellemann G, et al. Effects of antenatal depression and antidepressant treatment on gestational age at birth and risk of preterm birth. Am J Psychiatry. 2007;164(8):1206-13. [pmid: 17671283].
61 Ancel P, Saurel-Cubizolles M, Di Renzo G, Papiernik E, Breart G. Very and moderate preterm births: are the risk factors different?. Br J Obstet Gynaecol. 1999;106:1162-70. [pmid: 10549961].
62 Schlienger R, Fedson D, Jick S, Jick H, Meier C. Statins and the risk of pneumonia: a population-based, nested case-control study. Pharmacotherapy. 2007;27:325-32. [pmid: 17316144].
63 Blaas S, Mutterlein R, Weig J, et al. Extensively drug resistant tuberculosis in a high income country: a report of four unrelated cases. BMC Infect Dis. 2008;8:60-7. [pmid: 18454863].
64 Condos R, Hadgiangelis N, Leibert E, et al. Case series report of a linezolid-containing regimen for extensively drug-resistant tuberculosis. Chest. 2008;134:187-92. [pmid: 18628223].
65 Rahaman J, Narayansingh G, Roopnarinesingh S. Fetal outcome among obese parturients. Int J Gynaecol Obstet. 1990;31:227-30. [pmid: 1969362].
66 Dayan J, Creveuil C, Herlicoviez M, et al. Antenatal depression, a risk factor for prenatal delivery. Presse Med. 1999;28(31):1698. [pmid: 10554610].
67 Kim Y, Lee B, Park H. Risk factors for preterm birth in Korea: a multicenter prospective study. Gynecol Obstet Invest. 2005;60:206-12. [pmid: 16088197].
68 Norman R, Masters L, Milner C, Wang J, Davies M. Relative risk of conversion from normoglycaemia to impaired glucose tolerance or non-insulin dependent diabetes mellitus in polycystic ovarian syndrome. Hum Reprod. 2001;16(9):1995-8. [pmid: 11527911].
69 Wright A, Holberg C, Taussig L, Martinez F. Factors influencing the relation of infant feeding to asthma and recurrent wheeze in childhood. Thorax. 2001;56(3):192-7. [pmid: 11182011].
70 Arvanitakis Z, Schneider JA, Wilson RS, et al. Statins, incident Alzheimer disease, change in cognitive function, and neuropathology. Neurology. 2008;70(19 Pt 2):1795-802. [pmid: 18199831].
71 Agresti A. Categorical data analysis. New York. John Wiley & Sons. 2002.
72 Sterne JA, Juni P, Schulz KF, et al. Statistical methods for assessing the influence of study characteristics on treatment effects in ‘meta-epidemiological’ research. Stat Med. 2002;21(11):1513-24. [pmid: 12111917].
73 Schulz KF, Altman DG, Moher D. CONSORT 2010 statement: updated guidelines for reporting parallel group randomised trials. BMJ. 2010;340:c332. [pmid: 20332509].
74 Hamm MP, Hartling L, Milne A, et al. A descriptive analysis of a representative sample of pediatric randomized controlled trials published in 2007. BMC Pediatr. 2010;10:96. [pmid: 21176224].
75 Crocetti MT, Amin DD, Scherer R. Assessment of risk of bias among pediatric randomized controlled trials. Pediatrics. 2010;126(2):298-305. [pmid: 20624806].
76 Stang A. Critical evaluation of the Newcastle-Ottawa scale for the assessment of the quality of nonrandomized studies in meta-analyses. Eur J Epidemiol. 2010;25(9):603-5. [pmid: 20652370].
77 Schunemann HJ, Brozek J, Oxman AD. GRADE handbook for grading quality of evidence and strength of recommendation. Version 3.2 [update March 2009] ed. The Grade Working Group. 2009. Available from: http://www.gradeworkinggroup.org/index.html.
78 Berkman ND, Viswanathan M. Development of a tool to evaluate the quality of non-randomized studies of interventions or exposures. AHRQ 2009 Annual Conference. Sept 15, 2009. Bethesda, MA. 2009.