# Peer Reviewers

Ethan Balk

Tufts Medical Center

Boston, MA

Tim Carey

University of North Carolina

Chapel Hill, NC

Rongwei (Rochelle) Fu

Oregon Health & Science University

Portland, OR

Tatyana Shamliyan

University of Minnesota

Minneapolis, MN

Jonathan Sterne

University of Bristol

Bristol, UK