# Introduction

## Quality and Risk of Bias Assessment in Systematic Reviews

The internal validity of a study reflects the extent to which the design and conduct of the study have prevented bias(es).1 One of the key steps in a systematic review is assessment of a study's internal validity, or potential for bias. This assessment serves to: (1) identify the strengths and limitations of the included studies; (2) investigate, and potentially explain heterogeneity in findings across different studies included in a systematic review; and (3) grade the strength of evidence for a given question. The risk of bias assessment directly informs one of four key domains considered when assessing the strength of evidence.

With the increase in the number of published systematic reviews2 and development of systematic review methodology over the past 15 years,1 close attention has been paid to the methods for assessing internal validity. Until recently this has been referred to as “quality assessment” or “assessment of methodological quality.”1 In this context “quality” refers to “the confidence that the trial design, conduct, and analysis has minimized or avoided biases in its treatment comparisons.”3 To facilitate the assessment of methodological quality, a plethora of tools has emerged.3-6 Some of these tools were developed for specific study designs (e.g., randomized controlled trials (RCTs), cohort studies, case-control studies), while others were intended to be applied to a range of designs. The tools often incorporate characteristics that may be associated with bias; however, many tools also contain elements related to reporting (e.g., was the study population described) and design (e.g., was a sample size calculation performed) that are not related to bias.1 The Cochrane Collaboration recently developed a tool to assess the potential risk of bias in RCTs. The Risk of Bias (ROB) tool1 was developed to address some of the shortcomings of existing quality assessment instruments, including over-reliance on reporting rather than methods.

Several systematic reviews have catalogued and critiqued the numerous tools available to assess methodological quality, or risk of bias of primary studies. For example, a systematic review published in 2008 found 21 tools that have been designed to assess methodological quality or risk of bias in RCTs; however, the review noted that most were not “rigorously developed or tested for validity and reliability.”7 A systematic review of tools for quality assessment of nonrandomized studies identified 182 different tools but found that none of them covered all of the six prespecified domains considered critical for internal validity: “creation of groups, blinding, soundness of information, follow-up, analysis of comparability, analysis of outcome”.8 Further, the authors found the tools to be poorly developed with little attention to principles of scale development.8 The authors only recommended 6 of the 182 for use in systematic reviews; however, they noted that all needed to be modified prior to use.8 A more recent comprehensive review of quality assessment tools for nonrandomized studies identified 86 tools but found that only 15 percent were developed specifically for use in systematic reviews, 36 percent were developed for general critical appraisal, and 34 percent were developed for “single use in a specific context.”9

In summary, few existing tools have undergone extensive inter-rater reliability or validity testing. Moreover, the focus of much of the tool development or testing that has been done has been on criterion or face validity.1,6,10 Therefore it is unknown whether, or to what extent, the summary assessments based on these tools differentiate between studies with biased and unbiased results (i.e., studies that may over- or underestimate treatment effects).

There is a clear need for inter-rater reliability testing of different tools in order to enhance consistency in their application and interpretation across different systematic reviews. Further, validity testing is essential to ensure that the tools being used can identify studies with biased results. Finally, there is a need to determine inter-rater reliability and validity in order to support the uptake and use of individual tools that are recommended by the systematic review community, and specifically the ROB tool within the Evidence-based Practice Center (EPC) Program.

In this project we focused on two tools that are commonly used in systematic reviews. The Cochrane ROB tool was designed for RCTs and is the instrument recommended by The Cochrane Collaboration for use in systematic reviews of RCTs. The Newcastle-Ottawa Scale is commonly used for nonrandomized studies, specifically cohort and case-control studies. It has also been endorsed for use in systematic reviews of nonrandomized studies by The Cochrane Collaboration. In the sections that follow we describe these tools, their development, and any testing that has occurred.

### The Cochrane Risk of Bias Tool

The Cochrane Collaboration released a new tool in 2008 to assess the potential risk of bias in RCTs.1 In 2011, The Cochrane Collaboration released a new version of the ROB tool which incorporated modifications based on user testing and feedback.11 The original ROB tool was based on six domains: sequence generation, allocation concealment, blinding, incomplete outcome data, selective outcome reporting, and “other sources of bias” (e.g., design-specific risks of bias; early stopping for benefit; severe baseline imbalances; inappropriate influence of funders). The developers of the tool aimed to distinguish between actual methods of conducting the trials versus reporting. Furthermore, the choice of components for inclusion in the tool was based on empirical evidence demonstrating their association with effect estimates.

There is a growing body of evidence from methodological studies, and meta-epidemiological studies in particular, to quantify the extent to which different characteristics of a trial exaggerate treatment effects. Empirical evidence exists for the following characteristics: sequence generation; allocation concealment; blinding; incomplete outcome reporting; selective outcome reporting; and, inappropriate influence of the funder.11 Pooled results for four studies evaluating the association between sequence generation and effect estimates7,8,12,13 indicate that inadequate sequence generation results in overestimation of treatment effects by 12 percent (ratio of odds ratios [ROR] 0.88, 95% CI: 0.79 to 0.99).14 Pooled results for seven studies7,8,12,13,15-17 show that inadequate allocation concealment exaggerates treatment effects by 18 percent (ROR 0.82, 95% CI: 0.71 to 0.94),17 although this varies by outcome type.18,19 A set of seven studies that evaluated blinding7,8,12,13,15-17 indicated that trials not described as double-blind overestimate treatment effects by 9 percent (ROR 0.91, 95% CI: 0.83 to 1.0).17 The effects of missing outcome data and how missing data are managed have been investigated in a number of ways. Several studies have suggested that per protocol analyses may yield more favorable treatment estimates compared to intention-to-treat (ITT) analyses,20-22 and another study found that “modified” ITT versus ITT analyses exaggerated effect estimates by 15 percent (ROR 0.85, 95% CI: 0.81 to 0.88).23,30 Other studies have found no significant effects.7,8,13,15,24 A recent systematic review summarized five studies that followed inception cohorts from protocol to full publication in order to examine selective reporting of outcomes.25-30 Four of the studies found that statistically significant outcomes were more likely to be reported in full than nonsignificant outcomes (range of odds ratios: 2.2 to 4.7).28 A systematic review of trials stopped early for benefit provides empirical evidence that such trials overestimate treatment effects,31,32 although recent discussions have questioned whether early stopping is associated with bias. Reports of inappropriate influence of funders provide evidence that published research that is industry-sponsored is more likely to have results favoring the sponsor,33-35 and that they often have access to data during the conduct of a trial and authority to stop the trial at any point or prevent publication of trial results.36 The ongoing BRANDO study is focused on compiling a large body of meta-epidemiological work into a comprehensive database to enable large-scale investigation of associations between trial design features and effect estimates.37

Researchers at the University of Alberta Evidence-based Practice Center (EPC) evaluated the original Cochrane ROB tool in a sample of trials with a number of treatment conditions and showed that inter-rater agreement ranged from slight to substantial across the different domains, with the overall risk of bias assessment having ‘fair’ agreement.38 The authors further showed that treatment effect sizes (ES) differed: studies at high or unclear risk of bias reported significantly greater treatment effects (ES=0.52) than those at low risk of bias (ES=0.23). The authors identified sources of discrepancy and made recommendations in order to enhance the degree of consistency of the ROB tool. One of the stated limitations of this research was that the sample to which the tool was applied included only trials in children, the results of which may not be generalizable to trials conducted in other populations. A subsequent study by the same researchers showed improved inter-rater agreement on ROB assessments within the context of a systematic review.39 The authors suggested that the improved agreement may have resulted from review-specific guidelines and pilot-testing. No important patterns appeared in analyses comparing effect estimates and risk of bias; however, the ES were very homogeneous across the studies and there were very few studies in the sample that were at low risk of bias. This may have led to inadequate power to detect differences.

### The Newcastle-Ottawa Scale

The Newcastle-Ottawa Scale (NOS) is a quality assessment tool for use on nonrandomized studies included in systematic reviews, specifically cohort and case-control studies. The tool was produced by the combined efforts of the Universities of Newcastle, Australia and Ottawa, Canada40 and was first reported at the 3^rd^ Symposium for Systematic Reviews in Oxford, UK in 2000.^41^ Separate assessment criteria are available for case-control and cohort studies, and evaluate: the selection of participants, comparability of study groups, and the ascertainment of exposure (case-control studies) or outcome of interest (cohort studies). A star rating system is used to indicate the quality of a study, with a maximum assessment of nine stars.41 Each criterion receives a single star if appropriate methods have been reported. The selection domain is subdivided to evaluate the selection of the exposed and non-exposed cohorts, the ascertainment of exposure, and whether the study demonstrated that the outcome of interest was not present at the start of the study. Comparability is the only category that may receive two stars: one if the most important confounders have been adjusted for in the analysis and a second star if any other adjustments were made. Outcome of interest is made up of three questions: the appropriateness of the methods used to evaluate the outcome, the length of followup, and the degree of the loss to followup.40

The developers of the NOS have examined face and criterion validity, inter-rater reliability, and evaluator burden for the NOS. Face validity has been evaluated as strong by comparing each individual assessment item to their stem question. Criterion validity has shown a strong agreement with the Downs and Black assessment tool42 on a series of 10 cohort studies evaluating hormone replacement therapy in breast cancer, with an intra-class correlation (ICC) of 0.88. Inter-rater reliability for the NOS on cohort studies was high with an ICC of 0.94. Evaluator burden, as assessed by the time required to complete the NOS evaluation, was shown to be significantly less than the Downs and Black tool (p<0.001).43 The authors state that further assessment of the construct validity and the relationship between the external criterion of the NOS and its internal structures are under consideration.40 These studies have been presented as abstracts; at present no peer reviewed articles have been published investigating the psychometric properties of the NOS.

## Goal and Objective

We undertook this project to assess the reliability and validity of the two tools described above. We were interested in the reliability of risk of bias/quality assessments across individual raters, and between consensus agreements of individual raters. The scope of this work related to risk of bias or quality assessment of the primary therapeutic studies in systematic reviews of health care interventions. This work is directly relevant to the methods and interpretation of data in comparative effectiveness reviews and other evidence reports produced through the AHRQ Effective Health Care (EHC) Program. This project was done in collaboration with the University of Ottawa EPC, McMaster University EPC, and Southern California (SC)/RAND EPC.

The specific objectives were:

1. To assess the reliability of the Cochrane ROB tool for RCTs and the NOS for cohort studies between individual raters and, for the ROB tool, between the consensus agreements of individual raters (i.e., comparing consensus agreements across four EPCs).
2. To assess the validity of the Cochrane ROB tool and NOS by examining whether treatment effect estimates vary according to risk of bias or study quality. That is, were treatment effect estimates different for studies at high, unclear or low risk of bias based on the domains in the ROB tool, or for studies with different design characteristics based on the items of the NOS.
3. To examine the impact of study-level factors (e.g., outcomes, interventions, and conditions) on scale reliability and validity.