# Sources of Disagreement Across Consensus Assessments Using the Risk of Bias Tool

## General Observations

Sequence generation: Agreement was good overall. The main discrepancies were when the study described using stratification or block randomization, which would be assessed differently by different centers.

Allocation concealment: Discrepancies were mainly introduced when components of ‘sealed, sequentially numbered, opaque envelopes’ were reported, but not the full set of three elements.

Blinding: Some discrepancies were driven by having to combine assessments for participants/personnel and outcome assessors. If one group was blinded and the other wasn't, the RoB assessments varied by which group was interpreted as taking precedence. The other major source of discrepancies was the interpretation of unblinded studies (or unblinded groups) with objective outcomes, or those with subjective outcomes and blinded outcome assessors.

Incomplete outcome data: Discrepancies are largely due to different EPCs finding/using different information to make judgments.

Selective outcome reporting: Discrepancies are likely due to the interpretation by each EPC of how strictly to require ‘matching’ of outcomes in the Methods and Results sections.

Other sources of bias: In addressing source of funding, discrepancies were due to differences in interpretation. In addressing baseline characteristics, discrepancies were due to EPCs not finding the same information.

Table: Examples of sources of disagreement between consensus assessments

Author | Example
Sequence Generation
Bisser, S | All four EPCs noted block randomization – 2 interpreted as low RoB; 2 interpreted as unclear RoB
Pronyk, P | At least 1 reviewer from each EPC found the same description – 1 low; 2 unclear; 1 high RoB
Fagnani, F | Two EPCs found no description (unclear), while two EPCs found description of stratification but interpreted it differently (1 low; 1 high RoB)
Allocation Concealment
Gigantesco, A | At least 1 reviewer from each EPC found the description of central allocation – 2 low; 2 unclear RoB
Hartvig,P | Three EPCs found the same description – 2 interpreted as high RoB; 1 interpreted as low RoB, but this is likely a data entry error (1 reviewer said high, 1 said unclear); fourth EPC did not find description (unclear)
Baker, R | All four EPCs found the description of ‘sealed envelopes’ – 1 low; 2 unclear; 1 high RoB
Pronyk, P | The two EPCs that rated this domain unclear did not find the description; the two EPCs that rated the domain low RoB found the same information
Lim, Y | All four EPCs found the same description (sealed, opaque envelopes) – 3 interpreted as low RoB; 1 interpreted as high RoB
Hirose, Y | All four EPCs found the same description (numbered, sealed envelopes) – 1 low; 2 unclear; 1 high RoB
Blinding
Mentzer, R | Described as ‘double-blind’, but with an objective outcome – 2 interpreted as low RoB; 2 interpreted as unclear RoB
Bisser, S | Two EPCs rated as unclear RoB, but for different reasons; open-label with objective outcomes interpreted differently (1 low, 1 unclear RoB); 1 EPC rated as high RoB, but only 1 reviewer from all EPCs found the information that this decision was based on
Geyer, C | All four EPCs found the same description (open-label, blinded outcome assessor) – 2 low; 1 unclear; 1 high RoB
Pappone, C | Three EPCs found description of blinded outcome assessor (1 low, 1 unclear, 1 high RoB; the high also used additional information not found by the other reviewers); one EPC found no description of blinding (unclear)
Gigantesco, A | All four EPCs found description of blinded outcome assessors – 2 interpreted as low RoB; 2 interpreted as unclear RoB
Andersen, F | All four EPCs found the same description of blinding – 2 interpreted as low RoB; 2 interpreted as unclear RoB
Hartvig, P | Blinding not explicitly stated, but unlikely to have occurred – 2 interpreted as unclear RoB; 2 interpreted as high RoB
Carlbring, P | Three EPCs rated as high RoB since it was an unblinded study with a self-reported outcome; the other EPC rated as low RoB since there was a blinded outcome assessor
Hinman, R | Differing interpretations of how to assess an unblinded study with a subjective outcome, but blinded outcome assessor – 1 low; 1 unclear; 2 high RoB
Baker, R | Differing interpretations when blinding was not addressed and the outcome was self-reported – 2 unclear; 2 high RoB
Steinkruger, G | Differing interpretations when patients were blinded but others were not – 1 low; 2 unclear; 1 high RoB
Fregni, F | Differing interpretations when patients and personnel blinded, but no mention of outcome assessors – 2 low; 2 unclear RoB
Vassallo, B | One EPC did not find a description of blinding (unclear); two found a description of unblinded surgeons (high); one found a description of blinded surgeons (low)
Lim, Y | Described as double-blind, with specification that outcome assessor was blinded – 2 interpreted as low; 2 interpreted as unclear RoB
Fagnani, F | All four EPCs used the same description of blinding – 2 unclear; 2 high RoB
Olsen, E | One EPC found information on blinding (low); two did not find a description of specifics (unclear); one has no description (low)
Pialoux, V | No description of blinding (2 unclear; 1 high); one based assessment on objective outcome (low)
Incomplete Outcome Data
Mentzer, R | All four EPCs commented on analysis of ~90% of participants (2 low; 1 unclear; 1 high); EPC rating as high RoB stated that ITT was not mentioned
Geyer, C | Two EPCs report detailed description of losses to follow up (low); one mentions <90% follow-up (high); one has no description (unclear)
Martinez-Mier, G | Three EPCs report sufficient follow-up/analysis (2 low; 1 unclear – data entry error?); one found reporting unclear (unclear)
Pappone, C | Three EPCs report sufficient follow-up/analysis, but there were differences in interpretation of the study design (2 low; 1 high); one did not find details on drop-outs (unclear)
Andersen, F | Two EPCs found complete follow-up (low); two found insufficient information to judge (unclear)
Carlbring, P | One EPC questioned lack of data for the control group (high); three stated ITT analysis (low)
Kolak, M | One EPC was unclear on whether drop-outs would impact results (unclear); one did not find details on completers (unclear); one found a complete dataset (low); one had no description (low)
Hinman, R | Three EPCs stated that all participants were accounted for and ITT analysis was used (low); one reported <90% follow-up (high)
Baker, R | One EPC stated that drop-outs were imbalanced between groups and follow-up was <90% (high); one stated that follow-up was <90% (high); one was unclear on validity of stated reasons for drop-outs (unclear); one used 85% follow-up (low)
Pronyk, P | Two EPCs based judgment on low rate of individual follow-up (high); one based judgment on use of per protocol analysis (high); one based judgment on follow-up of clusters (low)
Hirose, Y | Three EPCs stated follow-up >90% (2 low; 1 unclear); one had no description (unclear)
King, V | Two EPCs stated follow-up <90% (high); one stated follow-up >90% (low); one had no description (unclear)
Kim, L | Three EPCs noted 81% follow-up (1 unclear; 2 high); one noted complete follow-up (low)
Miwa, H | All four EPCs noted the same description (2 unclear; 2 high)
Salvadori, M | Three EPCs stated high degree of loss to follow-up (high); one based judgment on modified ITT analysis (low)
Marsh, A | One EPC reported complete follow-up (low); three stated insufficient information to judge (2 unclear; 1 no)
Saari, T | All four EPCs note high rate of drop-out – 2 unclear; 2 high RoB
Iwase, T | Two EPCs stated complete follow-up (low); one stated insufficient information (unclear); one had no description (unclear)
Selective Outcome Reporting
Gigantesco, A | Two EPCs stated that the outcomes in the Methods matched those in the Results (low); two found that outcomes for the control group were not reported (unclear)
Hartvig, P | One EPC found missing data (high); two reported that all outcomes were reported (low); one found all outcomes reported but have a consensus decision of unclear RoB – likely a data entry error
Carlbring, P | Three EPCs found no evidence of selective outcome reporting (low); one found additional outcomes reported in the results section (high)
Kemppainen, T | Three EPCs found no evidence of selective outcome reporting (low); one found outcomes not reported in the results section (high)
Lim, Y | Two EPCs found no evidence of selective outcome reporting (low); two found outcomes not reported in the results section (high)
Olsen, E | Two EPCs found no evidence of selective outcome reporting (low); two found outcomes not reported in the results section (1 unclear; 1 high)
Saari, T | Two EPCs found no evidence of selective outcome reporting (low); two were unclear on the reporting (unclear)
Other Sources of Bias
Mentzer, R | All four EPCs addressed the potential conflict of interest regarding industry involvement – 2 unclear; 2 high RoB
Andersen, F | Differing interpretations of conflict of interest – 1 low; 2 unclear; 2 high RoB
Pronyk, P | Two EPCs addressed baseline imbalances (1 unclear; 1 high); two did not find any other sources of bias (2 low RoB)
Vassallo, B | Three EPCs reported no mention of baseline characteristics or source of funding (2 unclear; 1 low); one found no other sources of bias (low)
King, V | Three EPCs used the same information (2 low; 1 unclear); one based judgment on external validity (unclear)
Marsh, A | Two EPCs addressed baseline imbalances (unclear); two considered baseline characteristics to be balanced (low)
Saari, T | All four EPCs addressed issues with funding – 2 unclear; 2 high RoB
Iwase, T | Two EPCs found no other sources of bias (low); two reported no mention of baseline characteristics or source of funding (unclear)