# Inter-rater Reliability on Risk of Bias Assessments, by Domain and Study-level Variable With Confidence Intervals

The following table provides the same information as in Table 7 of the main report with 95% confidence intervals included.

Table Inter-rater reliability on risk of bias assessments, by domain and study-level variable with 95% confidence intervals

Variable | Risk of bias domain, κ (interpretation)^*^
| SG | AC | Blinding | Incomplete outcome data | SOR | Other
Overall | 0.79 (0.70, 0.88) (Su) | 0.24 (0.05, 0.43) (F) | 0.33 (0.17, 0.49) (F) | 0.34 (0.17, 0.52) (F) | 0.27 (0.06, 049) (F) | 0.24 (0.06, 0.41) (F)
Nature of intervention
Pharmacological | 0.82 (0.69, 0.96) (AP) | 0.26 (0.02, 0.50) (F) | 0.33 (0.08, 0.58) (F) | 0.36 (0.12, 0.61) (F) | 0.12 (-0.13, 0.37) (Sl) | 0.38 (0.16, 0.60) (F)
Nonpharmacological | 0.77 (0.63, 0.90) (Su) | 0.24 (-0.09, 0.57) (F) | 0.37 (0.17, 0.58) (F) | 0.26 (-0.03, 0.56) (F) | 0.36 (0.04, 0.69) (F) | -0.06 (-0.34, 0.22) (P)
p-value | 0.57 | 0.94 | 0.79 | 0.61 | 0.25 | 0.02
Nature of outcome
Objective | 0.71 (0.55, 0.87) (Su) | 0.22 (-0.05, 0.49) (F) | 0.54 (0.34, 0.74) (M) | 0.33 (0.09, 0.58) (F) | 0.41 (0.11, 0.70) (M) | 0.09 (-0.16, 0.33) (Sl)
Subjective | 0.88 (0.77, 0.98) (AP) | 0.27 (-0.01, 0.55) (F) | 0.18 (-0.05, 0.42) (Sl) | 0.32 (0.03, 0.60) (F) | 0.07 (-0.18, 0.33) (Sl) | 0.45 (0.22, 0.69) (M)
p-value | 0.09 | 0.81 | 0.02 | 0.93 | 0.09 | 0.04
Study design
Parallel | 0.78 (0.67, 0.89) (Su) | 0.32 (0.14, 0.50) (F) | 0.27 (0.08, 0.45) (F) | 0.32 (0.11, 0.53) (F) | 0.21 (-0.05, 0.47) (F) | 0.23 (0.04, 0.42) (F)
Other | 0.88 (0.64, 1.00) (AP) | -0.07 (-0.16, 0.03) (P) | 0.77 (0.57, 0.97) (Su) | 0.34 (-0.09, 0.76) (F) | 0.46 (0.11, 0.81) (M) | 0.30 (-0.09, 0.69) (F)
p-value | 0.47 | 0.0002 | 0.0004 | 0.94 | 0.26 | 0.75
Trial hypothesis
Efficacy/superiority | 0.79 (0.69, 0.90) (Su) | 0.24 (0.02, 0.47) (Sl) | 0.33 (0.15, 0.51) (F) | 0.32 (0.11, 0.53) (F) | 0.38 (0.14, 0.62) (F) | 0.25 (0.05, 0.45) (F)
Other | 0.81 (0.56, 1.00) (AP) | 0.29 (-0.11, 0.70) (F) | 0.44 (0.04, 0.83) (M) | 0.33 (-0.12, 0.78) (F) | -0.31 (-0.48, -0.14) (P) | 0.31 (-0.11, 0.74) (F)
p-value | 0.92 | 0.83 | 0.64 | 0.97 | <0.0001 | 0.79
Funding
Industry | 0.63 (0.40, 0.87) (M) | -0.10 (-0.50, 0.30) (P) | 0.52 (0.19, 0.86) (M) | 0.42 (0.11, 0.73) (M) | 0.51 (0.17, 0.85) (M) | 0.39 (0.09, 0.68) (F)
No industry | 0.85 (0.75, 0.95) (AP) | 0.38 (0.18, 0.58) (F) | 0.28 (0.10, 0.46) (F) | 0.29 (0.06, 0.52) (F) | 0.13 (-0.13, 0.40) (Sl) | 0.21 (-0.01, 0.43) (F)
p-value | 0.10 | 0.03 | 0.21 | 0.50 | 0.09 | 0.34

* AP=almost perfect, Su=substantial, M=moderate, F=fair, Sl=slight, P=poor;

AC = allocation concealment; SG = sequence generation; SOR = selective outcome reporting