# Data Used for Kappa Calculations

The following (Tables H-1 to H-7) are 3×3 tables which were the basis for the kappa calculations to assess inter-rater agreement between two reviewers. One table is provided for each domain. The number of studies (assessments made) was 124.

Table H-1 3×3 Table for Sequence Generation

| | Reviewer 2
| | Low | Unclear | High
Reviewer 1 | Low | 57 | 9 | -
Reviewer 1 | Unclear | 3 | 53 | 2
Reviewer 1 | High | - | - | -

Table H-2 3×3 Table for Allocation Concealment

| | Reviewer 2
| | Low | Unclear | High
Reviewer 1 | Low | 10 | 8 | -
Reviewer 1 | Unclear | 18 | 82 | 5
Reviewer 1 | High | - | 1 | -

Table H-3 3×3 Table for Blinding

| | Reviewer 2
| | Low | Unclear | High
Reviewer 1 | Low | 26 | 6 | 2
Reviewer 1 | Unclear | 27 | 35 | 14
Reviewer 1 | High | 5 | 2 | 7

Table H-4 3×3 Table for Incomplete Outcome Data

| | Reviewer 2
| | Low | Unclear | High
Reviewer 1 | Low | 60 | 24 | 9
Reviewer 1 | Unclear | 1 | 5 | 3
Reviewer 1 | High | 6 | 6 | 10

Table H-5 3×3 Table for Selective Outcome Reporting

| | Reviewer 2
| | Low | Unclear | High
Reviewer 1 | Low | 73 | 19 | 2
Reviewer 1 | Unclear | 12 | 4 | 2
Reviewer 1 | High | 6 | 2 | 4

Table H-6 3×3 Table for Other Sources of Bias

| | Reviewer 2
| | Low | Unclear | High
Reviewer 1 | Low | 22 | 14 | 3
Reviewer 1 | Unclear | 23 | 40 | 9
Reviewer 1 | High | 3 | 5 | 5

Table H-7 3×3 Table for Overall Risk of Bias

| | Reviewer 2
| | Low | Unclear | High
Reviewer 1 | Low | - | - | -
Reviewer 1 | Unclear | 2 | 50 | 30
Reviewer 1 | High | - | 15 | 27

The following (Tables H-8 to H-11) are 3×3 tables which were the basis for the kappa calculations to assess inter-rater agreement for overall risk of bias across the four EPCs. One table is provided for each EPC. The number of studies (assessments made) was 30. Table H-12 shows the summary of consensus assessment for the four EPCs.

Table H-8 3×3 Table for EPC1

| | Reviewer 2 | | | Consensus
| | Low | Unclear | High
Reviewer 1 | Low | - | - | - | -
Reviewer 1 | Unclear | - | 6 | 3 | 8 (unclear)
Reviewer 1 | High | - | 6 | 15 | 22 (high)

Table H-9 3×3 Table for EPC2

| | Reviewer 2 | | | Consensus
| | Low | Unclear | High
Reviewer 1 | Low | - | - | - | -
Reviewer 1 | Unclear | - | 7 | 4 | 15 (unclear)
Reviewer 1 | High | - | 10 | 9 | 15 (high)

Table H-10 3×3 Table for EPC3

| | Reviewer 2 | | | Consensus
| | Low | Unclear | High
Reviewer 1 | Low | - | 1 | 4 | -
Reviewer 1 | Unclear | - | 9 | 9 | 17 (unclear)
Reviewer 1 | High | - | 4 | 3 | 13 (high)

Table H-11 3×3 Table for EPC4

| | Reviewer 2 | | | Consensus
| | Low | Unclear | High
Reviewer 1 | Low | - | 1 | - | 1 (low
Reviewer 1 | Unclear | 1 | 12 | 3 | 19 (unclear)
Reviewer 1 | High | - | 6 | 7 | 10 (high)

Table H-12 Summary of consensus assessments for four EPCs

| Low | Unclear | High
EPC 1 | - | 8 | 22
EPC 2 | - | 15 | 15
EPC 3 | - | 17 | 13
EPC 4 | 1 | 19 | 10