# Description of Randomized Controlled Trials

Publication characteristics (N=154)

| | Overall risk of bias assessment
Variable | n (%) | High | Unclear | Low
Number of authors (mean, SD) | 6.8 (3.3)
Working group
Yes | 14 (9.1) | 11 | 3 | 0
No | 139 (90.9) | 61 | 78 | 1
Type of journal
General medical journal | 19 (12.3) | 10 | 9 | 0
Specialty medical journal | 135 (87.7) | 62 | 72 | 1
Country of corresponding author
Australia | 7 (4.6) | 5 | 2 | 0
Austria | 1 (0.7) | 1 | 0 | 0
Belgium | 1 (0.7) | 0 | 1 | 0
Canada | 3 (2.0) | 2 | 1 | 0
Chile | 1 (0.7) | 0 | 1 | 0
China | 6 (3.9) | 3 | 3 | 0
Denmark | 2 (1.3) | 1 | 1 | 0
Egypt | 1 (0.7) | 0 | 1 | 0
Finland | 1 (0.7) | 1 | 0 | 0
France | 4 (2.6) | 0 | 4 | 0
Germany | 6 (3.9) | 2 | 4 | 0
Greece | 4 (2.6) | 0 | 4 | 0
India | 1 (0.7) | 0 | 1 | 0
Iran | 2 (1.3) | 0 | 2 | 0
Italy | 13 (8.4) | 3 | 10 | 0
Japan | 5 (3.3) | 2 | 3 | 0
Mexico | 1 (0.7) | 0 | 1 | 0
the Netherlands | 6 (3.9) | 3 | 3 | 0
New Zealand | 1 (0.7) | 0 | 1 | 0
Norway | 3 (2.0) | 1 | 2 | 0
Poland | 1 (0.7) | 0 | 1 | 0
Scotland | 1 (0.7) | 0 | 1 | 0
Singapore | 3 (2.0) | 1 | 2 | 0
South Africa | 2 (1.3) | 2 | 0 | 0
South Korea | 2 (1.3) | 0 | 2 | 0
Spain | 2 (1.3) | 1 | 1 | 0
Sweden | 5 (3.2) | 3 | 2 | 0
Taiwan | 2 (1.3) | 0 | 2 | 0
Turkey | 5 (3.3) | 1 | 4 | 0
United Kingdom | 13 (8.4) | 7 | 6 | 0
U.S. | 49 (31.8) | 33 | 15 | 1
Impact factor (mean, SD) | 5.0 (7.6)

SD = standard deviation

Trial characteristics (N=154)

| | Overall risk of bias assessment
Variable | n (%) | High | Unclear | Low
Study design
RCT crossover | 21 (13.6) | 10 | 11 | 0
RCT factorial | 3 (2.0) | 2 | 1 | 0
RCT parallel | 126 (81.8) | 59 | 66 | 1
RCT split body | 4 (2.6) | 1 | 3 | 0
Study type
Efficacy/Superiority | 130 (84.4) | 61 | 69 | 0
Equivalence | 9 (5.8) | 4 | 4 | 1
Non-inferiority | 2 (1.3) | 2 | 0 | 0
None of the above | 6 (3.9) | 1 | 5 | 0
Unclear | 7 (4.5) | 4 | 3 | 0
Unit of randomization
Cluster | 7 (4.6) | 5 | 2 | 0
Individual | 147 (95.5) | 67 | 79 | 1
Nature of intervention
Behavioral/Psychological | 17 (11.0) | 9 | 8 | 0
Device | 10 (6.5) | 3 | 7 | 0
Drug | 82 (53.3) | 42 | 39 | 1
Natural health product | 6 (3.9) | 1 | 5 | 0
Surgical | 18 (11.7) | 7 | 11 | 0
Vaccine | 1 (0.7) | 1 | 0 | 0
Other | 20 (13.0) | 9 | 11 | 0
Intervention type
Nonpharmacological | 67 (43.5) | 29 | 38 | 0
Pharmacological | 87 (56.5) | 43 | 43 | 1
Dosing
Fixed dose | 79 (51.3) | 38 | 40 | 1
Flexible dose | 31 (20.1) | 13 | 18 | 0
Not applicable | 41 (26.6) | 21 | 20 | 0
Unclear | 3 (2.0) | 0 | 3 | 0
Placebo controlled
Yes | 55 (35.7) | 27 | 27 | 1
No | 97 (63.0) | 45 | 52 | 0
Unclear | 2 (1.3) | 0 | 2 | 0
Number of arms (median, range) | 2 (2-7)
Multicenter
Yes | 40 (26.0) | 25 | 14 | 1
No | 100 (64.9) | 40 | 60 | 0
Unclear | 14 (9.1) | 7 | 7 | 0
Number of centers (range) | 1-327
Multinational
Yes | 7 (4.6) | 5 | 2 | 0
No | 147 (95.5) | 67 | 79 | 1
Sample size (median, IQR) | 63 (39-123)
Sample size calculation reported
Yes | 80 (51.9) | 40 | 39 | 1
No | 74 (48.1) | 32 | 42 | 0
Funding source (all that apply)
Academic | 18 (11.7) | 6 | 12 | 0
Foundation | 26 (16.9) | 11 | 15 | 0
Government | 40 (26.0) | 22 | 18 | 0
Industry | 42 (27.3) | 33 | 9 | 0
No funding | 7 (4.6) | 3 | 3 | 1
Not declared | 47 (30.5) | 13 | 34 | 0
Other | 8 (5.2) | 2 | 6 | 0

Primary Diagnostic Category | n (%)
Acute Respiratory Infections | 1 (0.7)
Airways | 6 (3.9)
Anesthesia | 5 (3.2)
Back | 1 (0.7)
Bone, Joint and Muscle Trauma | 4 (2.6)
Breast Cancer | 2 (1.3)
Colorectal Cancer | 5 (3.3)
Cystic Fibrosis and Genetic Disorders | 1 (0.7)
Depression, Anxiety and Neurosis | 6 (3.9)
Drugs and Alcohol | 3 (2.0)
Ear, Nose and Throat Disorders | 2 (1.3)
Exercise Physiology | 6 (3.9)
Eyes and Vision | 7 (4.6)
Fertility Regulation | 3 (2.0)
Gynecological Cancer | 1 (0.7)
HIV/AIDS | 2 (1.3)
Heart | 11 (7.1)
Hepato-Biliary | 4 (2.6)
Immune System | 3 (1.9)
Incontinence | 1 (0.7)
Infectious Diseases | 2 (1.3)
Inflammatory Bowel Disease and Function | 2 (1.3)
Lung Cancer | 1 (0.7)
Menstrual Disorders and Subfertility | 3 (2.0)
Metabolic and Endocrine Disorders | 6 (3.9)
Musculoskeletal | 8 (5.2)
Neuromuscular Disease | 1 (0.7)
Oral Health | 3 (2.0)
Other | 17 (11.0)
Pain, Palliative and Supportive Care | 1 (0.7)
Peripheral Vascular Diseases | 4 (2.6)
Pregnancy and Childbirth | 5 (3.3)
Prostatic Diseases and Urologic Cancers | 1 (0.7)
Public Health | 1 (0.7)
Renal | 7 (4.6)
Schizophrenia | 4 (2.6)
Skin | 6 (3.9)
Stroke | 4 (2.6)
Tobacco Addiction | 1 (0.7)
Upper Gastrointestinal and Pancreatic Diseases | 2 (0.7)
Wounds | 1 (0.7)

RCT = randomized controlled trial

Outcomes and conclusions (N=154)

| | Overall risk of bias assessment
Variable | n (%) | High | Unclear | Low
Primary outcome
Objective | 74 (48.1) | 33 | 41 | 0
Subjective | 80 (51.9) | 39 | 40 | 1
Source of outcome assessment
Administrative data | 7 (4.6) | 4 | 3 | 0
Automated data | 21 (13.6) | 10 | 11 | 0
Clinician assessment | 54 (35.1) | 24 | 29 | 1
Laboratory measure | 36 (23.4) | 14 | 22 | 0
Self-report | 36 (23.4) | 21 | 15 | 0

Risk of bias assessments by domain (N=161)^*^

| Risk of bias assessments - n (%)
Domain | High | Unclear | Low
Sequence generation | 1 (0.6) | 75 (46.6) | 85 (52.8)
Allocation concealment | 3 (1.9) | 124 (77.0) | 34 (21.1)
Blinding | 21 (13.0) | 79 (49.1) | 61 (37.9)
Incomplete data | 29 (18.0) | 30 (18.6) | 102 (63.4)
Selective reporting | 17 (10.6) | 19 (11.8) | 125 (77.6)
Other sources of bias | 33 (20.5) | 90 (55.9) | 38 (23.6)
Overall risk of bias | 74 (46.0) | 86 (53.4) | 1 (0.6)

* AII studies assessed for risk of bias

Risk of bias assessments by domain (N=154)^*^

| Risk of bias assessments - n (%)
Domain | High | Unclear | Low
Sequence generation | 0 (0.0) | 70 (45.5) | 84 (54.6)
Allocation concealment | 2 (1.3) | 119 (77.3) | 33 (21.4)
Blinding | 21 (13.6) | 75 (48.7) | 58 (37.7)
Incomplete data | 29 (18.8) | 27 (17.5) | 98 (63.6)
Selective reporting | 16 (10.4) | 19 (12.3) | 119 (77.3)
Other sources of bias | 33 (21.4) | 86 (55.8) | 35 (22.7)
Overall risk of bias | 72 (46.8) | 81 (52.6) | 1 (0.7)

* Non-intervention studies from original sample replaced with trials evaluating healthcare interventions