# Supplementary Information for NOS Assessments

Additional background information provided to study participants to assist in making quality assessments. Information was based on the initial systematic reviews, or where necessary, expert opinion.

Breastfeeding and Maternal and Infant Health Outcomes in Developed Countries (AHRQ Report Number 153)

Cardiac Resynchronization Therapy and Implantable Cardiac Defibrillators in Left Ventricular Systolic Dysfunction (AHRQ Report Number 152)

Diagnosis, Prognosis, and Treatment of Impaired Glucose Tolerance and Impaired Fasting Glucose (AHRQ Report Number 128)

A Review and Meta-analysis of Prospective Studies of Red and Processed Meat Intake and Prostate Cancer (Alexander, Mink, Cushing, Sceurman. Nutrition Journal 2010;0:50)

A Meta-analysis of Depression During Pregnancy and the Risk of Preterm Birth, Low Birth Weight and Intrauterine Grown Restriction (Grote, Bridge, Gavin, Melville, Iyengar and Katon. Arch Gen Psychiatry 2010;67(10):1012-24)

Treatment Outcomes among Patients with Extensively Drug-Resistant Tuberculosis: Systematic Review and Meta-Analysis (Jacobson, Tierney, Jeon, Mitnick and Murray. Clinical Infectious Diseases 2010;51(1):6-14)

The effect of statins on mortality from severe infections and sepsis: A systematic review and meta-analysis (Janda, Young, FitzGerald, Etminan, Swiston. Journal of Critical Care 2010;25:656e7—656e22)

Overweight and Obesity in Mothers and Risk of Preterm Birth and Low Birth Weight Infants: Systematic Review and Meta-Analyses (McDonald, Han, Mulla, and Beyene. BMJ 2010;341:c3428)