# Meta-Analyses and Cohort Studies Used for NOS Assessments

## EPC Systematic Reviews

Ip S, Chung M, Raman G, Chew P, Magula N, DeVine D, Trikalinos T, Lau J. Breastfeeding and maternal and infant health outcomes in developed countries. Evidence Report/Technology Assessment No. 153 (Prepared by Tufts-New England Medical Center Evidence-based Practice Center, under Contract No. 290-02-0022). AHRQ Publication No. 07-E007. Rockville, MD: Agency for Healthcare Research and Quality. April 2007.

1 Burgess S, Dakin C, O'Callaghan M. Breastfeeding does not increase the risk of asthma at 14 years. Pediatrics. 2006;117(4):e787-92. [pmid: 16585289].
2 Fergusson D, Horwood L, Shannon F. Risk factors in childhood eczema. J Epidemiol Commun Health. 1982;36:118-2.
3 Gordon R, Nobel DQ, Ward AM, Allen R. Immunoglobulin E and the eczema-asthma syndrome in early childhood. Lancet. 1982;1:72-4. [pmid: 6119493].
4 Gruskay F. Comparison of breast, cow and soy feedings in the prevention of onset of allergic disease: a 15-year prospective study. Clin Pediatr. 1982;21(8):546-50.
5 Hide D, Guyer B. Clinical manifestations of allergy related to breast and cows' milk feeding. Arch Dis Child. 1981;56:172-5. [pmid: 6894227].
6 Kull I, Almqvist C, Lilja G. Breast-feeding reduces the risk of asthma during the first 4 years of life. J Allergy Clin Immunol. 2004;114(4):755-60. [pmid: 15480312].
7 Oddy W, Holt P, Sly P, et al. Association between breast feeding and asthma in 6 year old children: findings of a prospective birth cohort. BMJ. 1993;319:815-9. [pmid: 10496824].
8 Tariqu S, Matthews S, Hakim E, et al. The prevalence of and risk factors for atopy in early childhood: a whole population birth cohort study. J Allergy Clin Immunol. 1998;101:587-93. [pmid: 9600493].
9 Wilson A, Forsyth J, Greene S, et al. Relation of infant diet to childhood health: seven year follow up of cohort of children in Dundee infant feeding study. BMJ. 1998;316:21-5. [pmid: 9451261].
10 Wright A, Holberg C, Taussig L, Martinez F. Factors influencing the relation of infant feeding to asthma and recurrent wheeze in childhood. Thorax. 2001;56(3):192-7. [pmid: 11182011].

McAlister FA, Ezekowitz J, Dryden DM, Hooton N, Vandermeer B, Friesen C, Spooner C, Rowe BH. Cardiac resynchronization therapy and implantable cardiac defibrillators in left ventricular systolic dysfunction. Evidence Report/Technology Assessment No. 152 (Prepared by the University of Alberta Evidence-based Practice Center under Contract No. 290-02-0023). AHRQ Publication No. 07-E009. Rockville, MD: Agency for Healthcare Research and Quality. June 2007.

1 Bokhari F, Newman D, Greene M, et al. Long-term comparison of the implantable cardioveter defibrillator versus amiodarone: eleven-year follow-up of a subset of patients in the Canadian Implantable Defibrillator Study (CIDS). Circulation. 2004;110(2):112-6. [pmid: 15238454].
2 Buxton AE, Lee KL, Fisher JD, et al. A randomized study of the prevention of sudden death in patients with coronary artery disease. Multicenter Unsustained Tachycardia Trial Investigators. N Engl J Med. 1999;341(25):1882-90. [pmid: 10601507].
3 Chan P, Hayward R. Mortality reduction by implantable cardioveter-defibrillators in high-risk patients with heart failure, ischemic heart disease, and new-onset ventricular arrhythmia: an effectiveness study. J Am Coll Cardiol. 2005;45(9):1474-81. [pmid: 15862422].
4 Chan P, Chow T, Kereiakes D, et al. Effectiveness of implantable cardioconverter defibrillators in patients with ischemic heart disease and left ventricular dysfunction. Arch Intern Med. 2006;166(20):2228-33. [pmid: 17101941].
5 Ermis C, Zadeii G, Zhu A, et al. Improved survival of cardiac transplantation candidates with implantable cardioverter defibrillator therapy: role of beta-blocker or aminodarone treatment. J Cardiovasc Electrophysiol. 2003;14(6):578-83. [pmid: 12875416].
6 Ermis C, Lurie K, Zhu A, et al. Biventricular implantable cardioverter defibrillators improve survival compared with biventricular pacing alone in patients with severe left ventricular dysfunction. J Cardiovasc Electrophysiol. 2004;15(8):862-6. [pmid: 15333075].
7 Gaita F, Bocchiardo M, Porciani M, et al. Should stimulation therapy for congestive heart failure be combined with defibrillation backup?. Am J Cardiol. 2000;86(9A):165K-8K.
8 Pappone C, Vicedomini G, Augello G, et al. Combining electrical therapies for advanced heart failure: the Milan experience with biventricular pacing-defibrillation backup combination for primary prevention of sudden cardiac death. Am J Cardiol. 2003;91(9A):74F-80F.
9 Raviele A, Bongiorni M, Brignole M, et al. Early EPS/ICD strategy in survivors of acute myocardial infarction with severe left ventricular dysfunction on optimal beta-blocker treatment. The Beta-blocker Strategy plus ICD trial. Europace. 2005;7(4):327-37. [pmid: 16028343].
10 Saba S, Atiga W, Barrington W, et al. Selected patients listed for cardiac transplantation may benefit from defibrillator implantation regardless of an established indication. J Heart Lung Transplant. 2003;22(4):411-18. [pmid: 12681418].
11 Sanchez JM, Katsiyiannis WT, Gage BF, et al. Implantable cardioverter-defibrillator therapy improves long-term survival in patients with unexplained syncope, cardiomyopathy, and a negative electrophysiologic study. Heart Rhythm. 2005;2(4):367-73. [pmid: 15851337].

Santaguida PL, Balion C, Hunt D, Morrison K, Gerstein H, Raina P, Booker L, Yazdi H. Diagnosis, prognosis, and treatment of impaired glucose tolerance and impaired fasting glucose. Evidence Report/Technology Assessment No. 128. (Prepared by the McMaster University Evidence-based Practice Center under Contract No. 290-02-0020). AHRQ Pub. No 05-E026-2. Rockville, MD: Agency for Healthcare Research and Quality. September 2005.

1 Ammari F, Batieha A, Jaddou P, Okashi M, Ajlouni K. A natural history of impaired glucose tolerance in North Jordan. Pracit Diabet Int. 1998;15(5):139-40.
2 Charles M, Eschwege E, Thibult N, et al. The role of non-esterfied fatty acids in the deterioration of glucose tolerance in Caucasian subjects: results of the Pairs Prospective Study. Diabetologia. 1997;40(9):1101-6. [pmid: 9300248].
3 Chou P, Li C, Wu G, Tsai S. Progression to type 2 diabetes among high-risk groups in Kin-Chen Kinmen. Exploring the natural history of type 2 diabetes. Diabet Care. 1988;21(7):1183-7.
4 de Vegt F, Dekker J, Jager A, et al. Relation of impaired fasting and postload glucose with incident type 2 diabetes in a Dutch population: The Hoorn Study. JAMA. 2001;285(16):2109-13. [pmid: 11311100].
5 Ferrannini E, Nannipieti M, Williams K, et al. Mode of onset of type 2 diabetes from normal or impaired glucose tolerance. Diabetes. 2004;53(1):160-5. [pmid: 14693710].
6 Haffner S, Miettinen H, Gaskill S, Stern M. Decreased insulin secretion and increased insulin resistance are independently related to the 7-year risk of NIDDM in Mexican-Americans. Diabetes. 1995;44(12):1386-91. [pmid: 7589843].
7 Inoue I, Takahashi K, Katayama S, et al. A higher proinsulin response to glucose loading predicts deteriorating fasting plasma glucose and worsening to diabetes in subjects with impaired glucose tolerance. Diabet Med. 1996;13(4):330-6. [pmid: 9162608].
8 Kahn S, Leonetti D, Prigeon R, et al. Proinsulin levels predict the development of non-insulin-dependent diabetes mellitus (NIDDM) in Japanese-American men. Diabet Med. 1996;13(9 Suppl 6):S63-6. [pmid: 8894485].
9 King H, Zimmet P, Raper L, Balkau B. The natural history of impaired glucose tolerance in the Micronesian population of Nauru: a six-year follow-up study. Diabetologia. 1984;26(1):39-43. [pmid: 6706044].
10 Ko G, Chan J, Tsang L, Cockram C. Combined use of fasting plasma glucose and HbA1c predicts the progression to diabetes in Chinese subjects. Diabet Care. 2000;21(7):1770-3.
11 Mykkanen L, Kuusisto J, Pyorala K, Laakso M. Cardiovascular disease risk factors as predictors of type 2 (non-insulindependent) diabetes mellitus in elderly subjects. Diabetologia. 1993;36(6):553-9. [pmid: 8335178].
12 Norman R, Masters L, Milner C, Wang J, Davies M. Relative risk of conversion from normoglycaemia to impaired glucose tolerance or non-insulin dependent diabetes mellitus in polycystic ovarian syndrome. Hum Reprod. 2001;16(9):1995-98. [pmid: 11527911].
13 Puavilai G, Tiewtranon V, Pensuwan S, et al. Impaired glucose tolerance in Thai adults: status of glucose tolerance after 2-year follow up. J Med Assoc Thai. 1987;7(Suppl 2):68-76. [pmid: 3298521].
14 Saad M, Knowler W, Pettitt D, Nelson R, Bennett P. Transient impaired glucose tolerance in Pima Indians: is it important?. BMJ. 1988;297(6661):1438-41. [pmid: 3147006].
15 Schranz A. Abnormal glucose tolerance in the Maltese. A population-based longitudinal study of the natural history of NIDDM and IGT in Malta. Diabetes Res Clin Pract. 1989;7(1):7-16. [pmid: 2752891].
16 Wat N, Lam T, Janus E, Lam K. Central obesity predicts the worsening of glycemia in southern Chinese. Int J Obes Relat Metabl Disord. 2001;25(12):1789-93.
17 Wong M, Gu K, Heng D, et al. The Singapore impaired glucose tolerance follow-up study: does the ticking clock go backward as well as forward?. Diabet Care. 2003;26(11):3024-30.

## Non-EPC Systematic Reviews

Alexander DD, Mink PJ, Cushing CA, Sceurman B. A review and meta-analysis of prospective studies of red and processed meat intake and prostate cancer. Nutrition Journal 2010:9:50.

1 Allen N, Key T, Appleby P, et al. Animal foods, protein, calcium and prostate cancer risk: the European Prospective Investigation into Cancer and Nutrition. Brit J Cancer. 2008;98(9):1574-81. [pmid: 18382426].
2 Allen N, Sauvaget N, Roddam A, et al. A propsective study of diet and prostate cancer in Japanese men. Cancer Causes Control. 2011;15(9):911-20. [pmid: 15577293].
3 Chan J, Pietinen P, Virtanen M, et al. Diet and prostate cancer risk in a cohort of smokers, with a specific focus on calcium and phosphorus (Finland). Cancer Causes Control. 2000;11(9):859-67. [pmid: 11075876].
4 Cross A, Peters U, Kirsch V, et al. A prospective study of meat and meat mutagens and prostate cancer risk. Cancer Res. 2005;65(24):11779-84. [pmid: 16357191].
5 Cross A, Leitzmann M, Gail M, et al. A prospective study of red and processed meat intake in relation to cancer risk. PLoS Med. 2007;4(12):1973-84.
6 Gann P, Hennekens C, Sacks F, et al. Propsective study of plasma fatty acids and risk of prostate cancer. J Natl Cancer Institute. 1994;86(4):281-6.
7 Hsing A, McLaughlin J, Schuman L, et al. Diet, tobacco use, and fatal prostate cancer: results from the Lutheran Brotherhood Cohort Study. Cancer Res. 1990;50(2 1):6836-40. [pmid: 2208150].
8 Koutros S, Cross A, Sandler D, et al. Meat and meat mutagens and risk of prostate cancer in the Agricultural Health Study. Cancer Epidemiol Biomarkers Prev. 2008;17(1):80-7. [pmid: 18199713].
9 LeMarchand L, Kolonel L, Wilkens L, Myers B, Hirohata T. Animal fat consumption and prostate cancer: a prospective study in Hawaii. Epidemiology. 1994;5(3):276-82. [pmid: 8038241].
10 Michaud D, Augustsson K, Rimm E, et al. A prospective study on intake of animal products and risk of prostate cancer. Cancer Causes Control. 2001;12(6):557-67. [pmid: 11519764].
11 Mills P, Beeson W, Phillips R, Fraser G. Cohort study of diet, lifestyle, and prostate cancer in Adventist men. Cancer. 1989;64(3):598-604. [pmid: 2743254].
12 Park S, Murphy S, Wilkens L, Henderson B, Kolonel L. Fat and meat intake and prostate cancer risk: the multiethnic cohort study. Int J Cancer. 2007;121(6):1339-45. [pmid: 17487838].
13 Rodriquez C, McCullough M, Mondul A, et al. Meat consumption among Black and White men and risk of prostate cancer in the Cancer Prevention Study II Nutrition Cohort. Cancer Epidemiol Biomarkers Prev. 2006;15(2):211-16. [pmid: 16492907].
14 Rohrmann S, Platz E, Kavanaugh C, et al. Meat and dairy consumption and subsequent risk of prostate cancer in a US cohort study. Cancer Causes Control. 18(1):41-50. [pmid: 17315319].
15 Schuurmann A, van den Brandt P, Dorant E, Goldbohm R. Animal products, calcium and prostate cancer risk in The Netherlands Cohort Study. Br J Cancer. 1999;80(7):1107-13. [pmid: 10362125].

Grote NK, Bridge JA, Gavin AR, Melville JL, Iyengar S, Katon WJ. A meta-analysis of depression during pregnancy and the risk of preterm birth, low birth weight and intrauterine growth restriction. Arch Gen Psychiatry 2010;76(10):1012-24.

1 Andersson L, Sundstrom-Poromaa I, Wulff M, Astrom M, Bixo M. Neonatal outcome following maternal antenatal depression and anxiety: a population-based study. Am J Epidemiol. 2004;159(9):872-81. [pmid: 15105180].
2 Copper R, Goldenberg R, Das A, et al. The preterm prediction study: maternal stress is associated with spontaneous preterm birth at less than thirty-five weeks' gestation. Am J Obstet Gynecol. 1996;175(5):1286-92. [pmid: 8942502].
3 Dayan J, Creveuil C, Marks M, et al. Prenatal depression, prenatal anxiety, and spontaneous preterm birth: a prospective cohort study among women with early and regular care. Pyschosom Med. 2006;68(6):938-46.
4 Dayan J, Creveuil C, Herlicoviez M, et al. Antenatal depression, a risk factor for prenatal delivery. Presse Med. 1999;28(31):1698. [pmid: 10554610].
5 Diego M, Field T, Hernandez-Reif M, et al. Prenatal depression restricts fetal growth. Early Hum Dev. 2009;85(1):65-70. [pmid: 18723301].
6 Dole N, Savitz D, Hert-Picciotto I, et al. Maternal stress and preterm birth. Am J Epidemiol. 2003;157(1):14-24. [pmid: 12505886].
7 Gavin A, Holzman C, Siefert K, Tian Y. Maternal depressive symptoms, depression, and psychiatric medication use in relation to risk of preterm delivery. Women's Health Issues. 2009;16(5):325-34. [pmid: 19733802].
8 Hass J, Fuentes-Afflick ESA, Jackson R, et al. Prepregnancy health status and the risk of preterm delivery. Arch Pediatr Adolesc. 2005;159(1):58-63.
9 Hedegaard M, Henriksen T, Sabroe S, Secher N. Psychological distress in pregnancy and preterm delivery. BMJ. 1993;307(6898):234-39. [pmid: 8369684].
10 Hoffman S, Hatch M. Depressive symptomatology during pregnancy: evidence for an association with decreased fetal growth in pregnancies of lower social class women. Health Psychol. 2000;19(6):535-43. [pmid: 11129356].
11 Jesse D, Seaver W, Wallace D. Maternal psychosocial risks predict preterm birth in a group of women from Appalachia. Midwifery. 2003;19(3):191-202. [pmid: 12946335].
12 Li D, Liu L, Odouli R. Presence of depressive symptoms during early pregnancy and the risk of preterm delivery: a prospective cohort study. Hum Reprod. 2009;24(1):146-53. [pmid: 18948314].
13 Neggers Y, Goldenberg R, Cliver S, Hauth J. The relationship between psychosocial profile, health practices, and pregnancy outcomes. Acta Obstet Gynecol Scand. 2006;85(3):277-85. [pmid: 16553174].
14 Nordentoft M, Lou H, Hansen D, et al. Intrauterine growth retardation and premature delivery: the influence of maternal smoking and pyschosocial factors. Am J Pub Health. 1996;86(3):347-54. [pmid: 8604759].
15 Orr S, James S, Blackmore Prince C. Maternal prenatal depressive symptoms and spontaneous preterm births among African-American women in Baltimore, Maryland. Am J Epidemiol. 2002;156(9):797-802. [pmid: 12396996].
16 Perkin M, Bland J, Peacock J, Anderson H. The effect of anxiety and depression during pregnancy on obstetric complications. Br J Obstet Gynaecol. 1993;100(7):629-34. [pmid: 8369244].
17 Rondo P, Ferreira R, Nogueira F, et al. Maternal psychological stress and distress as predictors of low birth weight, prematurity and intrautering growth retardation. Eur J Clin Nutr. 2003;57(2):266-72. [pmid: 12571658].
18 Steer R, Scholl T, Hediger M, Fischer R. Self-reported depression and negative pregnancy outcomes. J Clin Epidemiol. 1992;45(10):1092-99.
19 Suri R, Altshuler L, Hellemann G, et al. Effects of antenatal depression and antidepressant treatment on gestational age at birth and risk of preterm birth. Am J Psychiatry. 2007;164(8):1206-13. [pmid: 17671283].
20 Wisner KL, Sit DK, Hanusa BH, et al. Major depression and antidepressant treatment: impact on pregnancy and neonatal outcomes. Am J Psychiatry. 2009;166(5):557-66. [pmid: 19289451].

Jacobson KR, Tierney DB, Jeon CY, Mitnick CD, Murray MB. Treatment outcomes among patients with extensively drug-resistant tuberculosis: systematic review and meta-analysis. Clin Infect Disease 2010: 51(1):6-14.

1 Bamerjee R, Allen J, Westenhouse J, et al. Extensively drug-resistant tuberculosis in California, 1993-2006. Clin Infect Dis. 2008;47:450-7. [pmid: 18616396].
2 Blaas S, Mutterlein R, Weig J, et al. Extensively drug resistant tuberculosis in a high income country: a report of four unrelated cases. BMC Infect Dis. 2008;8:60-7. [pmid: 18454863].
3 Chan E, Strand M, Iseman M. Multidrug-resistant tuberculosis (TB) resistant to fluoroquinolones and streptomycin but susceptible to second-line injection therapy has a better prognosis than extensively drug-resistent TB. Clin Infect Dis. 2009;48:e50-2. [pmid: 19191632].
4 Condos R, Hadgiangelis N, Leibert E, et al. Case series report of a linezolid-containing regimen for extensively drug-resistant tuberculosis. Chest. 2008;134:187-92. [pmid: 18628223].
5 Eker B, Ortmann J, Migliori G, et al. Multidrug- and extensively drug-resistant tuberculosis, Germany. Emerg Infect Dis. 2008;14:1700-06. [pmid: 18976552].
6 Joen D, Kim D, Kang H, et al. Survival and predictions of outcomes in non-HIV-infected patients with extensively drug-resistant tuberculosis. Int J Tuberc Lung. 2009;13:594-600.
7 Kershavjee S, Gelmanova I, Mishustin S, et al. Treatment of extensively drug-resistant tuberculosis in Tomsk, Russia: a retrospective cohort study. Lancet. 2008;372:1403-9. [pmid: 18723218].
8 Kim D, Kim H, Park S, et al. Treatment outcomes and long-term survival in patients with extensively drug-resistant tuberculosis. Am J Respir Crit Care. 2008;178:1075-82.
9 Kim H, Hwang S, Kim H, et al. Impact of extensive drug resistance on treatment outcomes in non-HIV-infected patients with multidrug-resistant tuberculosis. Clin Infect Dis. 2007;45:1290-5. [pmid: 17968823].
10 Kliiman K, Altaja A. Predictors of poor treatment outcome in highly drug-resistant pulmonary tuberculosis. Eur Respir. 2009;33:1085-97.
11 Kwon Y, Kim Y, Suh G, et al. Treatment outcomes for HIV-uninfected patients with multidrug-resistant and extensively drug-resistant tuberculosis. Clin Infect Dis. 2008;47:496-502. [pmid: 18611154].
12 Mitnick C, Shin S, Seung K, et al. Comprehensive treatment of extensively drug-resistant tuberculosis. N Engl J Med. 2008;359:563-74. [pmid: 18687637].
13 Shah N, Pratt R, Armstrong L, et al. Extensively drug-resistant tuberculosis in the United States, 1993-2007. JAMA. 2008;300:2153-60. [pmid: 19001626].

Janda S, Young A, Fitzgerald JM, Etminan M, Swiston J. The effect of statins on mortality from severe infections and sepsis: a systematic review and meta-analysis. J Crit Care 2010:25:656.e7-656.e22.

1 Almog Y, Novack V, Eisinger M, et al. The effect of statin therapy on infection-related mortality in patients with atherosclerotic diseases. Crit Care Med. 2007;35:372-8. [pmid: 17205009].
2 Chalmers J, Singanayagam A, Murray M, Hill A. Prior statin use is associated with improved outcomes in community-acquired pneumonia. Am J Med. 2008;121:1002-1007. e1001. [pmid: 18954848].
3 Dobesh P, Klepser D, McGuire T, Morgan C, Olsen K. Reduction in mortality associated with statin therapy in patients with severe sepsis. Pharmacotherapy. 2009;29:621-30. [pmid: 19476415].
4 Donnino M, Cocchi M, Howell M, et al. Statin therapy is associated with decreased mortality in patients with infection. Acad Emerg Med. 2009;16:230-4. [pmid: 19281494].
5 Fernandez R, De Pedro V, Artigas A. Statin therapy prior to ICU admission: protection against infection or a severity marker?. Intensive Care Med. 2006;32:160-4. [pmid: 16086178].
6 Frost FJ, Petersen H, Tollestrup K, et al. Influenza and COPD mortality protection as pleiotropic, dose-dependent effects of statins. Chest. 2007;131(4):1006-12. [pmid: 17426203].
7 Hackam D, Mamdani M, Li P, Redelmeier D. Statin therapy prior to ICU admission: protection against infection or a severity marker?. Lancet. 2006;367:413-8. [pmid: 16458766].
8 Hsu J, Andes D, Knasinski V, Pirsch J, Safdar N. Statins are associated with improved outcomes of bloodstream infection in solid-organ transplant recipients. Eur J Clin Microbiol Infect Dis. 2009;28:1343-51. [pmid: 19669657].
9 Kruger P, Fitzsimmons K, Cook D, Jones M, Nimmo G. Statin therapy is associated with fewer deaths in patients with bacteraemia. Intensive Care Med. 2006;32:75-9. [pmid: 16283159].
10 Liappis A, Kan V, Rochester C, Simon G. The effect of statins on mortality in patients with bacteremia. Clin Infect Dis. 2001;33:1352-7. [pmid: 11565076].
11 Majumdar S, McAlister F, Eurich D, Padwal R, Marrie T. Statins and outcomes in patients admitted to hospital with community acquired pneumonia: population based prospective cohort study. BMJ. 2006;333:999. [pmid: 17060337].
12 Martin C, Talbert R, Burgess D, Peters J. Effectiveness of statins in reducing the rate of sever sepsis: a retrospective evaluation. Pharmacotherapy. 2007;27:20-6. [pmid: 17192158].
13 Mortensen E, Restrepo M, Anzueto A, Pugh J. The effect of prior statin use on 30-day mortality for patients with hospitalized with community-acquired pneumonia. Respir Res. 2005;6:82. [pmid: 16042797].
14 Mortensen E, Restrepo M, Copeland L, et al. Impact of previous statin and angiotensin II receptor blocker use on mortality in patients hospitalized with sepsis. Pharmacotherapy. 2007;27:1619-26. [pmid: 18041882].
15 Mortensen E, Pugh M, Copeland L, et al. Impact of statins and angiotensin-converting enzyme inhibitors on mortality of subjects hospitalized with pneumonia. Eur Respir. 2008;31:611-7.
16 Schlienger R, Fedson D, Jick S, Jick H, Meier C. Statins and the risk of pneumonia: a population-based, nested case-control study. Pharmacotherapy. 2007;27:325-32. [pmid: 17316144].
17 Thomsen R, Hundborg H, Johnsen S, et al. Statin use and mortality within 180 days after bacteremia: a population-based cohort study. Crit Care Med. 2006;34:1080-6. [pmid: 16484926].
18 Thomsen R, Riis A, Kornum J, et al. Preadmission use of statins and outcomes after hospitalization with pneumonia: population-based cohort study of 29.900 patients. Arch Intern Med. 2008;168:2081-7. [pmid: 18955636].
19 Tseng MY, Hutchinson PJ, Czosnyka M, et al. Effects of acute pravastatin treatment on intensity of rescue therapy, length of inpatient stay, and 6-month outcome in patients after aneurysmal subarachnoid hemorrhage. Stroke. 2007;38(5):1545-50. [pmid: 17413047].
20 Yang K, Chien J, Tseng W, et al. Statins do not improve short-arm survival in an oriental population with sepsis. Am J Emerg Med. 2007;25:494-501. [pmid: 17543651].

McDonald SD, Han Z, Mulla S, Beyene J. Overweight and obesity in mothers and risk of preterm birth and low birth weight infants: systematic review and meta-analysis. BMJ: 2010;341:c3428.

1 Adams M, Sarno A, Harlass F, Rawlings J, Read J. Risk factors for preterm delivery in a healthy cohort. Epidemiology. 1995;6(5):525-32. [pmid: 8562630].
2 Ancel P, Saurel-Cubizolles M, Di Renzo G, Papiernik E, Breart G. Very and moderate preterm births: are the risk factors different?. Br J Obstet Gynaecol. 1999;106:1162-70. [pmid: 10549961].
3 Baeten J, Bukusi E, Lambe M. Pregnancy complications and outcomes among overweight and obese nulliparious women. Am J Pub Health. 2001;91:436-40. [pmid: 11236410].
4 Barros H, Tavares M, Rodrigues T. Role of prenatal care in preterm birth and low birthweight in Portugal. J Public Health Med. 1996;18(3):321-8. [pmid: 8887844].
5 Berkowitz G, Blackmore Prince C, Lapinski R, Savitz D. Risk factors for preterm birth subtypes. Epidemiology. 1998;9(3):279-85. [pmid: 9583419].
6 Bhattacharya S, Campbell D, Liston A, Bhattacharya S. Effect of body mass index on pregnancy outcomes in nulliparous women. BMC Public Health. 2007;7:168. [pmid: 17650297].
7 Bianco A, Smilen S, Davis Y, et al. Pregnancy outcome and weight gain recommendations for the morbidly obese woman. Obstet Gynecol. 1998;91(1):97-102. [pmid: 9464729].
8 Bondevik G, Lie R, Ulstein M, Kvale G. Maternal hematological status and risk of low birth weight and preterm delivery in Nepal. Acta Obstet Gynecol Scand. 2001;80:402-8. [pmid: 11328215].
9 Callaway L, Prins J, Chang A, McIntyre H. The prevalence and impact of overweight and obesity in an Australian obstetric population. MJA. 2006;184:56-9. [pmid: 16411868].
10 Clausen T, Oyen N, Henriksen T. Pregnancy complications by overweight and residential area. A prospective study of an urban Norwegian cohort. Acta Obstet Gynecol Scand. 2006;85:526-33. [pmid: 16752229].
11 De B, Lin S, Lohsoonthorn V, Williams M. Risk of preterm delivery in relation to maternal low birth weight. Acta Obstet Gynecol Scand. 2007;86:565-71. [pmid: 17464585].
12 Dietz P, Callaghan W, Cogswell M, et al. Combined effects of prepregnancy body mass index and weight gain during pregnancy on the risk for preterm delivery. Epidemiology. 2006;17:170-7. [pmid: 16477257].
13 Druil L, Cacciaguerra G, Citossi A, et al. Prepregnancy body mass index and adverse pregnancy outcomes. Arch Gynecol Obstet. 2008;278:23-6. [pmid: 18071728].
14 Gardosi J, Francis A. Early pregnancy predictors of preterm birth: the role of a prolonged menstruation-conception interval. BJOG. 2000;107(2):228-37. [pmid: 10688507].
15 Gilboa S, Correa A, Alverson C. Use of spline regression in an analysis of maternal prepregnancy body mass index and adverse birth outcomes: does it tell us more than we already know?. Ann Epidemiol. 2008;18:196-205. [pmid: 18201903].
16 Goldenberg R, Iams J, Mercer B, et al. The preterm prediction study: the value of new vs standard risk factors in predicting early and all spontaneous preterm births. NICHD MFMU Network. Am J Pub Health. 1998;88:233-8. [pmid: 9491013].
17 Haas J, Fuentes-Afflick E, Stewart A, et al. Prepregnancy health status and the risk of preterm delivery. Arch Pediatr Adolesc. 2005;159:59-63.
18 Hauger M, Gibbons L, Vik T, Belizan J. Prepregnancy weight status and the risk of adverse pregnancy outcome. Acta Obstet Gynecol Scand. 2008;87:953-9. [pmid: 18720038].
19 Hendler I, Goldenberg R, Mercer B, et al. The Preterm Prediction Study: association between maternal body mass index and spontaneous and indicated preterm birth. Am J Obstet Gynecol. 2005;192:882-6. [pmid: 15746686].
20 Hickey C, Cliver S, McNeal S, Goldenberg R. Low pregravid body mass index as a risk factor for preterm birth: variation by ethnic group. Obstet Gynecol. 1997;89:206-12. [pmid: 9015021].
21 Jensen D, Damm P, Sorensen B, et al. Pregnancy outcome and prepregnancy body mass index in 2459 glucose-tolerant Danish women. Am J Obstet Gynecol. 2003;189:239-44. [pmid: 12861169].
22 Kim Y, Lee B, Park H. Risk factors for preterm birth in Korea: a multicenter prospective study. Gynecol Obstet Invest. 2005;60:206-12. [pmid: 16088197].
23 Leung T, Leung T, Sahota D, et al. Trends in maternal obesity and associated risks of adverse pregnancy outcomes in a population of Chinese women. BJOG. 2008;115:1529-37. [pmid: 19035989].
24 Lumme R, Paua R. Pre-pregnancy weight and its relation to pregnancy outcome. J Obstet Gynaecol. 1995;15:69-75.
25 Merlino A, Laffineuse L, Collin M, Mercer B. Impact of weight loss between pregnancies on recurrent preterm birth. Am J Obstet Gynecol. 2006;195:818-21. [pmid: 16949418].
26 Monaghan S, Little R, Hulchiy O, Strassner H, Gladen B. Risk factors for spontaneous preterm birth in two urban areas of Ukraine. Paediatr Perinat Epidemiol. 2001;15:123-30. [pmid: 11383576].
27 Nohr E, Bech H, Vaeth M, et al. Obesity, gestational weight gain and preterm birth: a study within the Danish National Birth Cohort. Paediatr Perinat Epidemiol. 2007;21:5-14. [pmid: 17239174].
28 Rahaman J, Narayansingh GV, Roopnarinesingh S. Fetal outcome among obese parturients. Int J Gynaecol Obstet. 1990;31(3):227-30. [pmid: 1969362].
29 Ray J, Vermeulen M, Shapiro J, Kenshole A. Maternal and neonatal outcomes in pregestational and gestational diabetes mellitus, and the influence of maternal obesity and weight gain: the DEPOSIT study: Diabetes Endocrine Pregnancy Outcome Study in Toronto. Q J Med. 2001;94:347-56.
30 Ronnenberg A, Wang X, Xing H, et al. Low preconception body mass index is associated with birth outcome in a prospective cohort of Chinese women. J Nutr. 2003;133:3449-55. [pmid: 14608057].
31 Sahu M, Agarwal A, Das V, Pandey A. Impact of maternal body mass index on obstetric outcome. J Obstet Gynaecol. 2007;33:655-9.
32 Savitz D, Dole N, Herring A, et al. Should spontaneous and medically indicated preterm births be separated for studying aetiology. Paediatr Perinat Epidemiol. 2005;19:97-105. [pmid: 15787884].
33 Scholl T, Hediger M, Salmon R, Belsky D, Ances I. Influence of prepregnant body mass and weight gain for gestation on spontaneous preterm delivery and duration of gestation during adolescent pregnancy. Am J Hum Biol. 1989;1:657-64.
34 Sebire N, Jolly M, Harris J, et al. Maternal obesity and pregnancy outcome a study of 287,213 pregnancies in London. Int J Obes Relat Metabl Disord. 2001;25:1175-82.
35 Siega-Riz A, Adair L, Hobel C. Maternal underweight status and inadequate rate of weight gain during the third trimester of pregnancy increases the risk of preterm delivery. J Nutr. 1996;126:146-53. [pmid: 8558295].
36 Smith G, Shah I, Pell J, Crossley J, Dobbie R. Maternal obesity in early pregnancy and risk of spontaneous and elective preterm deliveries: a retrospective cohort study. Am J Pub Health. 2007;97:157-62. [pmid: 17138924].
37 Yekta Z, Ayatollah H, Porali R, Farzin A. The effect of pre-pregnancy body mass index and gestational weight gain on pregnancy outcomes in urban care settings in Irma-Iran. BMC Pregnancy Childbirth. 2006;6:15. [pmid: 16626498].
38 Yogev Y, Langer O, Xenakis E, Rosenn B. The association between glucose challenge test, obesity and pregnancy outcome in 6390 non-diabetic women. J Matern Fetal Neonatal Med. 2005;17:29-34. [pmid: 15804783].