# Variables for Data Extraction from Randomized Controlled Trials

VALIDITY OF RISK OF BIAS: DATA EXTRACTION GUIDE
Field | Response | Comments
Publication characteristics
Please enter the following publication characteristics: RefID Publication title: Publication year: Citation: Full journal title: First author: Country of corresponding author: Number of authors: Was there a working group? Type of journal: Impact factor: RefID PubTitle PubDate Citation Journal LeadAuthor GeoLocation NumAuthors | □ Yes; □ No; □ General medical journal; □ Specialty medical journal
Trial characteristics
What is the study design? | □ RCT parallel; □ RCT crossover; □ RCT factorial; □ RCT split body | RCT parallel: A trial that compares two groups of people concurrently, one of which receives the intervention of interest and one of which is a control group. Some parallel trials have more than two comparison groups and some compare different interventions without including a non-intervention control group. (Also called independent group design.) RCT crossover: A type of clinical trial comparing two or more interventions in which the participants, upon completion of the course of one treatment, are switched to another. For example, for a comparison of treatments A and B, the participants are randomly allocated to receive them in either the order A, B or the order B, A. Particularly appropriate for study of treatment options for relatively stable health problems. The time during which the first intervention is taken is known as the first period, with the second intervention being taken during the second period.
Based on the study hypothesis/objectives, which study type is described by the authors? | □ Efficacy/Superiority; □ Equivalence; □ Non-inferiority; □ Not declared; □ None of the above; □ Unclear | Efficacy/Superiority: A study in which the authors intended to demonstrate a statistically significant difference between treatments. Equivalence: A study in which the authors intended to show that there was no statistically significant difference between treatments. Non-inferiority: A study in which the authors intended to show that the new treatment effect is not worse than the standard treatment effect.
In your opinion, what study type is consistent with the methods described? | □ Efficacy/Superiority; □ Equivalence; □ Non-inferiority; □ None of the above; □ Unclear | I.e., in your opinion, is the study type consistent with what the authors have classified it as?
What is the unit of randomization? | □ Individual; □ Cluster | Cluster RCTs could include randomization of classrooms or schools, practices or hospitals, etc.
What is the nature of the intervention? | □ Behavioral/Psychological; □ Device; □ Drug; □ Natural health product; □ Surgical; □ Vaccine; □ Other | Natural health products include:; - Vitamins and minerals; - Herbal remedies; - Homeopathic medicines; - Traditional medicines such as traditional Chinese medicines; - Probiotics, and; - Other products like amino acids and essential fatty acids.; (http://www.hc-sc.gc.ca/dhp-mps/prodnatur/index-eng.php) A device is “an instrument, apparatus, implement, machine, contrivance, implant, in vitro reagent, or other similar or related article, including a component part, or accessory which is:; - recognized in the official National Formulary, or the United States Pharmacopoeia, or any supplement to them,; - intended for use in the diagnosis of disease or other conditions, or in the cure, mitigation, treatment, or prevention of disease, in man or other animals, or; - intended to affect the structure or any function of the body of man or other animals, and which does not achieve any of it's primary intended purposes through chemical action within or on the body of man or other animals and which is not dependent upon being metabolized for the achievement of any of its primary intended purposes.”; (http://www.fda.gov/CDRH/DEVADVICE/312.html)
What is the intervention type? | □ Pharmacological; □ Nonpharmacological | Pharmacological includes drugs, natural health products, vaccines Non-pharmacological includes behavioural/educational, devices, surgical
Was the treatment mode a: | □ Flexible dose; □ Fixed dose; □ Unclear; □ N/A
What intervention(s) are tested? | | Specify the intervention(s) evaluated in the trial
Is the study placebo controlled? | □ Yes; □ No; □ Unclear
How many arms does the study have?
Is the study multicenter? | □ Yes; □ No; □ Unclear
If yes, how many study sites are involved?
Is the study multinational? | □ One country; □ Multinational
What is the enrolled sample size?
Is a sample size calculation reported? | □ Yes; □ No
What is the primary/secondary diagnostic category involved in the study? | □ Acute Respiratory Infections; □ Airways; □ Anaesthesia; □ Back; □ Bone, Joint and Muscle Trauma; □ Breast Cancer; □ Colorectal Cancer; □ Consumers and Communication; □ Cystic Fibrosis and Genetic Disorders; □ Dementia and Cognitive Improvement; □ Depression, Anxiety and Neurosis; □ Developmental, Psychosocial and Learning Problems; □ Drugs and Alcohol; □ Ear, Nose and Throat Disorders; □ Effective Practice and Organisation of Care; □ Epilepsy; □ Eyes and Vision; □ Fertility Regulation; □ Gynaecological Cancer; □ HIV/AIDS; □ Haematological Malignancies; □ Heart; □ Hepato-Biliary; □ Hypertension; □ Incontinence; □ Infectious Diseases; □ Inflammatory Bowel Disease and Functional Bowel Disorders; □ Injuries; □ Lung Cancer; □ Menstrual Disorders and Subfertility; □ Metabolic and Endocrine Disorders; □ Movement Disorders; □ Multiple Sclerosis; □ Musculoskeletal; □ Neuromuscular Disease; □ Occupational Safety and Health; □ Oral Health; □ Pain, Palliative and Supportive Care; □ Peripheral Vascular Diseases; □ Pregnancy and Childbirth; □ Prostatic Diseases and Urologic Cancers; □ Public Health; □ Renal; □ Schizophrenia; □ Sexually Transmitted Diseases; □ Skin; □ Stroke; □ Tobacco Addiction; □ Upper Gastrointestinal and Pancreatic Diseases; □ Wounds; □ Other
Specify condition being treated:
What was the treatment duration?
What is the funding source? | □ Industry; □ Government; □ Academic; □ Foundation; □ No funding; □ Other; □ Not declared
Specify source of funding:
Outcomes and conclusions
Primary outcome:
Is the primary outcome: | □ Objective; □ Subjective | Objective outcomes include all cause mortality, measures based on a recognized laboratory procedure, surgical or instrumental outcomes and other objective measures. Subjective outcomes include patient reported outcomes, physician assessed disease outcomes, measures combined from several outcomes, and withdrawals or study dropouts. (Wood et al. BMJ 2008;336:601-605.)
Source of outcome assessment: | □ Administrative data; □ Automated data; □ Clinician's assessment; □ Laboratory measure; □ Self-report; □ Other
What is the effect estimate of the primary outcome?