# Guidelines for Risk of Bias Assessments

This table was taken from the Cochrane Handbook of Reviews of Effectiveness of Interventions (Table 8.5.c (modified): Criteria for judging risk of bias in the ‘Risk of bias’ assessment tool).10 The last column was added to provide decision rules specific to this project.

SEQUENCE GENERATION Was the allocation sequence adequately generated? (Short form: Adequate sequence generation?)
Criteria for a judgement of ‘YES’ (i.e. low risk of bias). | The investigators describe a random component in the sequence generation process such as:; - Referring to a random number table;; - Using a computer random number generator;; - Coin tossing;; - Shuffling cards or envelopes;; - Throwing dice;; - Drawing of lots;; - Minimization*.; *Minimization may be implemented without a random element, and this is considered to be equivalent to being random. | The investigators describe the use of stratification or permuted blocking (use of computer implied).
Criteria for the judgement of ‘NO’ (i.e. high risk of bias). | The investigators describe a non-random component in the sequence generation process. Usually, the description would involve some systematic, non-random approach, for example:; - Sequence generated by odd or even date of birth;; - Sequence generated by some rule based on date (or day) of admission;; - Sequence generated by some rule based on hospital or clinic record number.; Other non-random approaches happen much less frequently than the systematic approaches mentioned above and tend to be obvious. They usually involve judgement or some method of non-random categorization of participants, for example:; - Allocation by judgement of the clinician;; - Allocation by preference of the participant;; - Allocation based on the results of a laboratory test or a series of tests;; - Allocation by availability of the intervention.
Criteria for the judgement of ‘UNCLEAR’ (uncertain risk of bias). | Insufficient information about the sequence generation process to permit judgement of ‘Yes’ or ‘No’. | Description only includes ‘random’, ‘randomly generated’, ‘randomized’, etc.

ALLOCATION CONCEALMENT
Was allocation adequately concealed? (Short form: Allocation concealment?)
Criteria for a judgement of ‘YES’ (i.e. low risk of bias). | Participants and investigators enrolling participants could not foresee assignment because one of the following, or an equivalent method, was used to conceal allocation:; - Central allocation (including telephone, web-based and pharmacy-controlled randomization);; - Sequentially numbered drug containers of identical appearance;; - Sequentially numbered, opaque, sealed envelopes.
Criteria for the judgement of ‘NO’ (i.e. high risk of bias). | Participants or investigators enrolling participants could possibly foresee assignments and thus introduce selection bias, such as allocation based on:; - Using an open random allocation schedule (e.g. a list of random numbers);; - Assignment envelopes were used without appropriate safeguards (e.g. if envelopes were unsealed or non­opaque or not sequentially numbered);; - Alternation or rotation;; - Date of birth;; - Case record number;; - Any other explicitly unconcealed procedure.
Criteria for the judgement of ‘UNCLEAR’ (uncertain risk of bias). | Insufficient information to permit judgement of ‘Yes’ or ‘No’. This is usually the case if the method of concealment is not described or not described in sufficient detail to allow a definite judgement – for example if the use of assignment envelopes is described, but it remains unclear whether envelopes were sequentially numbered, opaque and sealed.

BLINDING OF PARTICIPANTS, PERSONNEL AND OUTCOME ASSESSORS
Was knowledge of the allocated interventions adequately prevented during the study? (Short form: Blinding?) **Assess this domain based on the pre-determined primary outcome**
Criteria for a judgement of ‘YES’ (i.e. low risk of bias). | Any one of the following:; - No blinding, but the review authors judge that the outcome and the outcome measurement are not likely to be influenced by lack of blinding;; - Blinding of participants and key study personnel ensured, and unlikely that the blinding could have been broken;; - Either participants or some key study personnel were not blinded, but outcome assessment was blinded and the non-blinding of others unlikely to introduce bias. | Investigators describe the use of a [underlined: matched] placebo or discuss how placebos were similar in some way (e.g., appearance, taste, etc.)
Criteria for the judgement of ‘NO’ (i.e. high risk of bias). | Any one of the following:; - No blinding or incomplete blinding, and the outcome or outcome measurement is likely to be influenced by lack of blinding;; - Blinding of key study participants and personnel attempted, but likely that the blinding could have been broken;; - Either participants or some key study personnel were not blinded, and the non-blinding of others likely to introduce bias.
Criteria for the judgement of ‘UNCLEAR’ (uncertain risk of bias). | Any one of the following:; - Insufficient information to permit judgement of ‘Yes’ or ‘No’;; - The study did not address this outcome. | Study is only described as ‘double-blind’ or ‘placebo-controlled’.

INCOMPLETE OUTCOME DATA Were incomplete outcome data adequately addressed? (Short form: Incomplete outcome data addressed?)
Criteria for a judgement of ‘YES’ (i.e. low risk of bias). | Any one of the following:; - No missing outcome data;; - Reasons for missing outcome data unlikely to be related to true outcome (for survival data, censoring unlikely to be introducing bias);; - Missing outcome data balanced in numbers across intervention groups, with similar reasons for missing data across groups;; - For dichotomous outcome data, the proportion of missing outcomes compared with observed event risk not enough to have a clinically relevant impact on the intervention effect estimate;; - For continuous outcome data, plausible effect size (difference in means or standardized difference in means) among missing outcomes not enough to have a clinically relevant impact on observed effect size;; - Missing data have been imputed using appropriate methods. | Any one of the following:; - ≥90%* of enrolled patients are included in the analysis AND withdrawals and reasons for withdrawals are balanced between groups and appear unrelated to outcome;; - A true intention-to-treat analysis was conducted.; *90% is used as a guideline.
Criteria for the judgement of ‘NO’ (i.e. high risk of bias). | Any one of the following:; - Reason for missing outcome data likely to be related to true outcome, with either imbalance in numbers or reasons for missing data across intervention groups;; - For dichotomous outcome data, the proportion of missing outcomes compared with observed event risk enough to induce clinically relevant bias in intervention effect estimate;; - For continuous outcome data, plausible effect size (difference in means or standardized difference in means) among missing outcomes enough to induce clinically relevant bias in observed effect size;; - ‘As-treated’ analysis done with substantial departure of the intervention received from that assigned at randomization;; - Potentially inappropriate application of simple imputation. | Any one of the following:; - <90%* of enrolled patients are included in the analysis;; - Substantial proportion of patients withdrew from the study, even if they are included in an ITT analysis.; *90% is used as a guideline.
Criteria for the judgement of ‘UNCLEAR’ (uncertain risk of bias). | Any one of the following:; - Insufficient reporting of attrition/exclusions to permit judgement of ‘Yes’ or ‘No’ (e.g. number randomized not stated, no reasons for missing data provided);; - The study did not address this outcome.

SELECTIVE OUTCOME REPORTING
Are reports of the study free of suggestion of selective outcome reporting? (Short form: Free of selective reporting?) **Assess this domain based on ALL study outcomes**
Criteria for a judgement of ‘YES’ (i.e. low risk of bias). | Any of the following:; - The study protocol is available and all of the study's pre-specified (primary and secondary) outcomes that are of interest in the review have been reported in the pre-specified way;; - The study protocol is not available but it is clear that the published reports include all expected outcomes, including those that were pre-specified (convincing text of this nature may be uncommon). | Outcomes described in the Methods section are reported on in the Results section.
Criteria for the judgement of ‘NO’ (i.e. high risk of bias). | Any one of the following:; - Not all of the study's pre-specified primary outcomes have been reported;; - One or more primary outcomes is reported using measurements, analysis methods or subsets of the data (e.g. subscales) that were not pre-specified;; - One or more reported primary outcomes were not pre-specified (unless clear justification for their reporting is provided, such as an unexpected adverse effect);; - One or more outcomes of interest in the review are reported incompletely so that they cannot be entered in a meta-analysis;; - The study report fails to include results for a key outcome that would be expected to have been reported for such a study.
Criteria for the judgement of ‘UNCLEAR’ (uncertain risk of bias). | Insufficient information to permit judgement of ‘Yes’ or ‘No’. It is likely that the majority of studies will fall into this category.

OTHER POTENTIAL THREATS TO VALIDITY
Was the study apparently free of other problems that could put it at a risk of bias? (Short form: Free of other bias?) **Assess this domain based on: design-specific risks of bias; early stopping for benefit; severe baseline imbalances; inappropriate influence of funders** (a full list and other potential biases are provided in Section 8.14.1.6 of the Cochrane Handbook). Record any other potential sources that you feel may compromise the internal validity of a given study.
Criteria for a judgement of ‘YES’ (i.e. low risk of bias). | The study appears to be free of other sources of bias. | With respect to “inappropriate influence of study sponsors”, any one of the following:; - The study received no funding;; - The study was only funded by non-industry (e.g., government);; - The study declares the source of funding and the role of the sponsor (i.e., specifies that sponsor was removed from the conduct of the study).
Criteria for the judgement of ‘NO’ (i.e. high risk of bias). | There is at least one important risk of bias. For example, the study:; - Had a potential source of bias related to the specific study design used; or; - Stopped early due to some data-dependent process (including a formal-stopping rule); or; - Had extreme baseline imbalance; or; - Has been claimed to have been fraudulent; or; - Had some other problem. | With respect to “inappropriate influence of study sponsors”, any one of the following:; - One or more of the authors are industry employees or are receiving speaking grants;; - The sponsor is directly involved in the conduct of the trial.
Criteria for the judgement of ‘UNCLEAR’ (uncertain risk of bias). | There may be a risk of bias, but there is either:; - Insufficient information to assess whether an important risk of bias exists; or; - Insufficient rationale or evidence that an identified problem will introduce bias. | With respect to “inappropriate influence of study sponsors”, any one of the following:; - There is no mention of the funding source;; - Industry funding is declared with no description of role in the study.