# Sample of Randomized Controlled Trials

The following are citations for the RCTs that were assessed using the Cochrane Risk of Bias tool. The 30 RCTs that were used to examine reliability of consensus assessments by individual reviewers are marked with an asterisk (*). Overall 154 RCTs were included in the final sample. We assessed 161 RCTs but replaced 7 of these as they did not evaluate therapeutic interventions (Beedie et al., Boardman et al., D'Souza et al., Dyke et al., Kamlin et al., Pierce et al., Umemura et al.).

1 Acevedo B, Gomez-Palomares J, Ricciarelli E, Hernandez E. Triggering ovulation with gonadotropin-releasing hormone agonists does not compromise embryo implantation rates. Fertil Steril. 2006;86(6):1682-7. [pmid: 17074344].
2 Adeboyeku D, Scott S, Hodson M. Open follow-up study of tobramycin nebuliser solution and colistin in patients with cystic fibrosis. J Cyst Fibros. 2006;5(4):261-3. [pmid: 16807142].
3 Andersen F, Hedegaard K, Petersen T, et al. Comparison of the effect of glycerol and triamcinolone acetonide on cumulative skin irritation in a randomized trial. J Am Acad Dermatol. 2006;56(2):228-35. [pmid: 17156893].
4 Argyriou A, Chroni E, Polychronopoulos P, et al. Efficacy of oxcarbazepine for prophylaxis against cumulative oxaliplatin-induced neuropathy. Neurology. 2006;67(12):2253-5. [pmid: 17190958].
5 Aslam S, Santha T, Leone A, Wilcox C. Effects of amlodipine and valsartan on oxidative stress and plasma methylarginines in end-stage renal disease patients on hemodialysis. Kidney Int. 2006;70(12):2109-15. [pmid: 17063175].
6 Baker R, Squires B, Gargan M, Bannister G. Total Hip Arthroplasty and Hemiarthroplasty in Mobile, Independent Patients with a Displaced Intracapsular Fracture of the Femoral Neck. A Randomized, Controlled Trial. J Bone Joint Surg Am. 2006;88(12):2583-9. [pmid: 17142407].
7 Baron J, Sandler R, Bresalier R, et al. A randomized trial of rofecoxib for the chemoprevention of colorectal adenomas. Gastroenterology. 2006;131(6):1674-82. [pmid: 17087947].
8 Barth M, Capelle H, Weidauer S, et al. Effect of Nicardipine Prolonged-Release Implants on Cerebral Vasospasm and Clinical Outcome After Severe Aneurysmal Subarachnoid Hemorrhage. Stroke. 2006;38(2):330-6. [pmid: 17185636].
9 Beedie C, Stuart E, Coleman D, Foad A. Placebo Effects of Caffeine on Cycling Performance. Med Sci Sports Exerc. 2006;38(12):2159-64. [pmid: 17146324].
10 Bertrand O, De Larochelliere R, Rodes-Cabau J, et al. A Randomized Study Comparing Same-Day Home Discharge and Abciximab Bolus Only to Overnight Hospitalization and Abciximab Bolus and Infusion After Transradial Coronary Stent Implantation. Circulation. 2006;114(24):2636-43. [pmid: 17145988].
11 Bisschop C, Montandon G, Guenard H. Expiratory muscles modulate negative expiratory pressure-induced flow during muscular exercise. Respir Physiol Neurobiol. 2006;154(3):453-66. [pmid: 16446126].
12 Bisser S, N'Siesi F, Lejon V, et al. Equivalence Trial of Melarsoprol and Nifurtimox Monotherapy and Combination Therapy for the Treatment of Second-Stage Trypanosoma brucei gambiense Sleeping Sickness. J Infect Dis. 2006;195(3):322-9. [pmid: 17205469].
13 Blackhurst D, Marais A. Concomitant consumption of red wine and polyunsaturated fatty acids in edible oil does not influence the peroxidation status of chylomicron lipids despite increasing plasma catechin concentration. Nutr Metab Cardiovasc Dis. 2006;16(8):550-8. [pmid: 17126771].
14 Boardman T, Catley D, Grobe J, Little T, Ahluwalia J. Using motivational interviewing with smokers: Do therapist behaviors relate to engagement and therapeutic alliance?. J Subst Abuse Treat. 2006;31(4):329-39. [pmid: 17084786].
15 Budweiser S, Moertl M, Jorres R, et al. Respiratory Muscle Training in Restrictive Thoracic Disease: A Randomized Controlled Trial. Arch Phys Med Rehabil. 2006;87(12):1559-65. [pmid: 17141634].
16 Cardinale D, Colombo A, Sandri M, et al. Prevention of high-dose chemotherapy-induced cardiotoxicity in high-risk patients by angiotensin-converting enzyme inhibition. Circulation. 2006;114(23):2474-81. [pmid: 17101852].
17 Carlbring P, Bohman S, Brunt S, et al. Remote Treatment of Panic Disorder: A Randomized Trial of Internet-Based Cognitive Behavior Therapy Supplemented With Telephone Calls. Am J Psychiatry. 2006;163(12):2119-25. [pmid: 17151163].
18 Christensen H, Griffiths K, Mackinnon A, Brittliffe K. Online randomized controlled trial of brief and full cognitive behaviour therapy for depression. Psychol Med. 2006;36(12):1737-46. [pmid: 16938144].
19 Chu M, Cosper P, Nakhuda G, Lobo R. A comparison of oral and transdermal short-term estrogen therapy in postmenopausal women with metabolic syndrome. Fertil Steril. 2006;86(6):1669-75. [pmid: 17074346].
20 Church C, Price C, Pandyan A, et al. Randomized Controlled Trial to Evaluate the Effect of Surface Neuromuscular Electrical Stimulation to the Shoulder After Acute Stroke. Stroke. 2006;37(12):2995-3001. [pmid: 17053181].
21 Clarenbach J, Reber M, Lutjohann D, von Bergmann K, Sudhop T. The lipid-lowering effect of ezetimibe in pure vegetarians. J Lipid Res. 2006;47(12):2820-4. [pmid: 16966491].
22 Coullet J, Guell J, Fournie P, et al. Iris-supported Phakic Lenses (Rigid vs Foldable Version) for Treating Moderately High Myopia: Randomized Paired Eye Comparison. Am J Ophthalmol. 2006;142(6):909-16. [pmid: 17049332].
23 D'Souza D, Gil R, Madonick S, et al. Enhanced Sensitivity to the Euphoric Effects of Alcohol in Schizophrenia. Neuropsychopharmacology. 2006;31(12):2767-75. [pmid: 16985503].
24 Damji K, Bovell A, Hodge W, et al. Selective laser trabeculoplasty versus argon laser trabeculoplasty: results from a 1-year randomised clinical trial. Br J Ophthalmol. 2006;90(12):1490-4. [pmid: 16899528].
25 Denberg T, Kim F, Flanigan R, et al. The Influence of Patient Race and Social Vulnerability on Urologist Treatment Recommendations in Localized Prostate Carcinoma. Med Care. 2006;44(12):1137-41. [pmid: 17122719].
26 di Visconte M, Di Bella R, Munegato G. Randomized, Prospective Trial Comparing 0.25 Percent Glycerin Trinitrate Ointment and Anal Cryothermal Dilators Only with 0.25 Percent Glycerin Trinitrate Ointment and Only with Anal Cryothermal Dilators in the Treatment of Chronic Anal Fissure: A Two-Yea. Dis Colon Rectum. 2006;49(12):1822-30. [pmid: 17096178].
27 Dolegowska B, Pikula E, Safranow K, et al. Metabolism of eicosanoids and their action on renal function during ischaemia and reperfusion: the effect of alprostadil. Prostaglandins Leukot Essent Fatty Acids. 2006;75(6):403-11. [pmid: 17011760].
28 Donatelli F, Schricker T, Parrella P, et al. Intraoperative Infusion of Amino Acids Induces Anabolism Independent of the Type of Anesthesia. Anesth Analg. 2006;103(6):1549-56. [pmid: 17122238].
29 Dyke C, Steinhubl S, Kleiman N, et al. First-in-Human Experience of an Antidote-Controlled Anticoagulant Using RNA Aptamer Technology A Phase 1a Pharmacodynamic Evaluation of a Drug-Antidote Pair for the Controlled Regulation of Factor Ixa Activity. Circulation. 2006;114(23):2490-7. [pmid: 17101847].
30 East J, Suzuki N, Arebi N, Bassett P, Saunders B. Position changes improve visibility during colonoscope withdrawal: a randomized, blinded, crossover trial. Gastrointest Endosc. 2006;65(2):263-9. [pmid: 17141772].
31 Elsebaie S, El-Sabae M, Esmat M, Nasr M, Kamel M. Modified endocystectomy versus pericystectomy in echinococcus granulosus liver cysts: a randomized controlled study, and the role of specific anti-hydatid IGG4 in detection of early recurrence. J Egypt Soc Parasitol. 2006;36(3):993-1006. [pmid: 17153708].
32 Engin-Ustun Y, Ustun Y, Mutlu Meydanli M, Kafkasli A. Effects of intranasal 17 beta-estradiol and raloxifene on lipid profile and fibrinogen in hypercholesterolemic postmenopausal women: a randomized, place-controlled clinical trial. Gynecol Endocrinol. 2006;22(12):676-9. [pmid: 17162709].
33 Fagnani F, Giombini A, De Cesare A, Pigozzi F, Di Salvo V. The Effects of a Whole-Body Vibration Program on Muscle Performance and Flexibility in Female Athletes. Am J Phys Med Rehabil. 2006;85(12):956-62. [pmid: 17117001].
34 Farmer C, Hampson G, Abbs I, et al. Late Low-Dose Steroid Withdrawal in Renal Transplant Recipients Increases Bone Formation and Bone Mineral Density. Am J Transplant. 2006;6(12):2929-36. [pmid: 17061994].
35 Federico P, Annalisa F, Guiseppe C, et al. Coagulation management in patients undergoing open heart surgery by activated clotting time and whole blood heparin concentration. Perfusion. 2006;21(5):285-90. [pmid: 17201083].
36 Firooz A, Khamesipour A, Nassiri-Kashani M, et al. Imiquimod in Combination With Meglumine Antimoniate for Cutaneous Leishmaniasis. A Randomized Assessor-Blind Controlled Trial. Arch Dermatol. 2006;142(12):1575-9. [pmid: 17178983].
37 Fiscella K, Eisinger S, Meldrum S, et al. Effect of mifepristone for symptomatic leiomyomata on quality of life and uterine size. Obstet Gynecol. 2006;108(6):1381-7. [pmid: 17138770].
38 Fregni F, Gimenes R, Valle A, et al. A Randomized, Sham-Controlled, Proof of Principle Study of Transcranial Direct Current Stimulation for the Treatment of Pain in Fibromyalgia. Arthritis Rheum. 2006;54(12):3988-98. [pmid: 17133529].
39 Friedmann P, Rose J, Hayaki J, et al. Training primary care clinicians in maintenance care for moderated alchocol use. J Gen Intern Med. 2006;21(12):1269-75. [pmid: 16965560].
40 Froum S, Wallace S, Elian N, Cho S, Tarnow D. Comparison of mineralized cancellous bone allograft (Puros) and anorganic bovine bone matrix (Bio-Oss) for sinus augmentation: histomorphography at 26 to 32 weeks after grafting. Int J Periodontics Restorative Dent. 2006;26(6):543-51. [pmid: 17243327].
41 Ge J, Li Y, Qian J, et al. Efficacy of emergent transcatheter transplantation of stem cells for treatment of acute myocardial infarction (TCT-STAMI). Heart. 2006;92(12):1764-7. [pmid: 16775089].
42 Gerhardt M, Gunka V, Miller R. Hemodynamic stability during labor and delivery with continous epidural infusion. J Am Osteopath Assoc. 2006;106(12):692-8. [pmid: 17242413].
43 Geyer C, Forster J, Lindquist D, et al. Lapatinib plus capecitabine for HER2-positive advanced breast cancer. N Engl J Med. 2006;355(26):2733-43. [pmid: 17192538].
44 Gigantesco A, Vittorielli M, Pioli R, et al. The VADO Approach in Psychiatric Rehabilitation: A Randomized Controlled Trial. Psychiatr Serv. 2006;57(12):1778-83. [pmid: 17158494].
45 Gnant M, Luschin-Ebengreuth G, Kaessmann H, et al. Zoledronic Acid Prevents Cancer Treatment–Induced Bone Loss in Premenopausal Women Receiving Adjuvant Endocrine Therapy for Hormone-Responsive Breast Cancer: A Report From the Austrian Breast and Colorectal Cancer Study Group. J Clin Oncol. 2006;25(7):820-8. [pmid: 17159195].
46 Goldberg R, Guyton J, Mazzone T, et al. Ezetimibe/Simvastatin vs Atorvastatin in Patients With Type 2 Diabetes Mellitus and Hypercholesterolemia: The VYTAL Study. Mayo Clin Proc. 2006;81(12):1579-88. [pmid: 17165637].
47 Granacher U, Gollhofer A, Strass D. Training induced adaptations in characteristics of postural reflexes in elderly men. Gait Posture. 2006;24(4):459-66. [pmid: 16472525].
48 Greenblatt D, Legangneux E, Harmatz J, et al. Dynamics and Kinetics of a Modified-Release Formulation of Zolpidem: Comparison With Immediate-Release Standard Zolpidem and Placebo. J Clin Pharmacol. 2006;46(12):1469-80. [pmid: 17101746].
49 Hart S, Mangoni A, Swift C, Jackson S. Lack of Significant Effects of Methionine Loading on Endothelial Function in Elderly Volunteers. Heart Lung Circ. 2006;15(6):358-61. [pmid: 17046324].
50 Hartvig P, Aulin J, Wallenberg S, Wagenius G. Physical exercise for cytotoxic drug-induced fatigue. J Oncol Pharm Pract. 2006;12(4):183-91. [pmid: 17156590].
51 Hayek S, Ritchey R, Sessler D, et al. Continous femoral nerve analgesia after unilateral total knee arthroplasty: stimulating versus nonstimulating catheters. Anesth Analg. 2006;103(6):1565-70. [pmid: 17122240].
52 Hayward A, Harling R, Wetten S, et al. Effectiveness of an influenza vaccine programme for care home staff to prevent death, morbidity, and health service use among residents: cluster randomised controlled trial. BMJ. 2006;333(7581):1241. [pmid: 17142257].
53 Heidari S, Saghaei M, Hashemi S, Parvazinia P. Effect of oral ketamine on the post-operative pain and analgesic requirement following orthopedic surgery. Acta Anaesthesiol Taiwan. 2006;44(4):211-5. [pmid: 17233365].
54 Henquet C, Rosa A, Krabbendam L, et al. An experimental study of catechol-O-methyltransferase Val158Met moderation of delta-9-tetrahydrocannabinol-induced effects on psychosis and cognition. Neuropsychopharmacology. 2006;31(12):2748-57. [pmid: 16936704].
55 Hinman R, Heywood S, Day A. Aquatic Physical Therapy for Hip and Knee Osteoarthritis: Results of a Single-Blind Randomized Controlled Trial. Phys Ther. 2006;87(1):32-43. [pmid: 17142642].
56 Hirose Y, Murosaki S, Yamamoto Y, Yoshikai Y, Tsuru T. Daily intake of heat-killed lactobacillus plantarum L-137 augments acquired immunity in healthy adults. J Nutr. 2006;136(12):3069-73. [pmid: 17116721].
57 Hoybye C, Rudling M. Long-term GH treatment of GH-deficient adults: Comparison between one and two daily injections. J Endocrinol Invest. 2006;29(11):950-6. [pmid: 17259790].
58 Hoyles R, Ellis R, Wellsbury J, et al. A Multicenter, Prospective, Randomized, Double-Blind, Placebo-Controlled Trial of Corticosteroids and Intravenous Cyclophosphamide Followed by Oral Azathioprine for the Treatment of Pulmonary Fibrosis in Scleroderma. Arthritis Rheum. 2006;54(12):3962-70. [pmid: 17133610].
59 Hsu K, Zucherman J, Hartjen C, et al. Quality of life of lumbar stenosis-treated patients in whom the X STOP interspinous device was implanted. J Neurosurg Spine. 2006;5(6):500-7. [pmid: 17176013].
60 Hui D, To K, Ko F. Nasal CPAP reduces systemic blood pressure in patients with obstructive sleep apnoea and mild sleepiness. Thorax. 2006;61(12):1083-90. [pmid: 16928705].
61 Iribarren O, Araujo M. Effect of Antimicrobial Prophylaxis on the Incidence of Infections in Clean Surgical Wounds in Hospitals Undergoing Renovation. Infect Control Hosp Epidemiol. 2006;27(12):1372-6. [pmid: 17152037].
62 Iwase T, Sugiyama K. Investigation of the stability of one-piece acrylic intraocular lenses in cataract surgery and in combined vitrectomy surgery. Br J Ophthalmol. 2006;90(12):1519-23. [pmid: 16914475].
63 Johnston M, Flook E, Mehta D, Mortimore S. Prospective randomised single-blind controlled trial of glacial acetic acid versus glacial acetic acid, neomycin sulphate and dexamethasone spray in otitis externa and infected mastoid cavities. Clin Otolaryngol. 2006;31(6):504-7. [pmid: 17184455].
64 Kamlin O, O'Donnell C, Everest N, Davis P, Morley C. Accuracy of clinical assessment of infant heart rate in the delivery room. Resuscitation. 2006;71(3):319-21. [pmid: 16989935].
65 Karaaslan D, Sivaci R, Akbulut G, Dilek O. Preemptive Analgesia in Laparoscopic Cholecystectomy: A Randomized Controlled Study. Pain Pract. 2006;6(4):237-41. [pmid: 17129304].
66 Karaca P, Yurtseven N, Enc Y, et al. Effects of different cardioplegic solutions on nitric oxide release from coronary vasculature in diabetic patients undergoing coronary artery bypass surgery. Anadolu Kardiyol Derg. 2006;6(4):347-51. [pmid: 17162282].
67 Karunakar M, Sen A, Bosse M, et al. Indometacin as prophylaxis for heterotopic ossification after the operative treatment of fractures of the acetabulum. J Bone Joint Surg Br. 2006;88-B(12):1613-7. [pmid: 17159174].
68 Kasje W, Denig P, Stewart R, de Graeff P, Haaijer-Ruskamp F. An educational programme for peer review groups to improve treatment of chronic heart failure and diabetes mellitus type 2 in general practice. J Eval Clin Pract. 2006;12(6):613-21. [pmid: 17100860].
69 Katznelson L, Robinson M, Coyle C, Lee H, Farrell C. Effects of modest testosterone supplementation and exercise for 12 weeks on body composition and quality of life in elderly men. Eur J Endocrinol. 2006;155(6):867-75. [pmid: 17132757].
70 Kemppainen T, Kokki H, Tuomilehto H, Seppa J, Nuutinen J. Acetaminophen is Highly Effective in Pain Treatment After Endoscopic Sinus Surgery. Laryngoscope. 2006;116(12):2125-8. [pmid: 17146383].
71 Kenefick R, O'Moore K, Mahood N, Castellani J. Rapid IV versus oral rehydration: responses to subsequent exercise heat stress. Med Sci Sports Exerc. 2006;38(12):2125-31. [pmid: 17146319].
72 Khachik F, de Moura F, Chew E, et al. The Effect of Lutein and Zeaxanthin Supplementation on Metabolites of These Carotenoids in the Serum of Persons Aged 60 or Older. Invest Ophthalmol Vis Sci. 2006;47(12):5234-42. [pmid: 17122108].
73 Kim L, Hilli L, Orlowski J, et al. Efficacy of Probiotics and Nutrients in Functional Gastrointestinal Disorders: A Preliminary Clinical Trial. Dig Dis Sci. 2006;51(12):2134-44. [pmid: 17078006].
74 King V, Kidorf M, Stoller K, et al. A 12-month controlled trial of methadone medical maintenance integrated into an adaptive treatment model. J Subst Abuse Treat. 2006;31(4):385-93. [pmid: 17084792].
75 Koh T, Butow P, Coory M, et al. Provision of taped conversations with neonatologists to mothers of babies in intensive care: randomised controlled trial. BMJ. 2006;334(7583):28. [pmid: 17142256].
76 Kolak M, Yki-Ja¨rvinen H, Kannisto K, et al. Effects of chronic rosiglitazone therapy on gene expression in human adipose tissue in vivo in patients with Type 2 Diabetes. J Clin Endocrinol Metab. 2006;92(2):720-4. [pmid: 17148569].
77 Koo S, Cho S, Kim Y, Ham K, Hwang J. Small-Dose Ketamine Reduces the Pain of Propofol Injection. Anesth Analg. 2006;103(6):1444-7. [pmid: 17122220].
78 Kornblith A, Dowell J, Herdon J, et al. Telephone Monitoring of Distress in Patients Aged 65 Years or Older With Advanced Stage Cancer. Cancer. 2006;107(11):2706-14. [pmid: 17078057].
79 Kraft M, Cairns C, Ellison M, et al. Improvements in Distal Lung Function Correlate With Asthma Symptoms After Treatment With Oral Montelukast*. Chest. 2006;130(6):1726-32. [pmid: 17166989].
80 Lederman M, Smeaton L, Smith K, et al. Cyclosporin A provides no sustained immunologic benefit to persons with chronic HIV-1 infection starting suppressive antiretroviral therapy: results of a randomized, controlled trial of the AIDS Clinical Trials Group A5138. J Infect Dis. 2006;194(12):1677-85. [pmid: 17109339].
81 Letzel H, Megard Y, Lamarca R, Raber A, Fortea J. The efficacy and safety of aceclofenac versus placebo and naproxen in women with primary dysmenorrhoea. Eur J Obstet Gynecol Reprod Biol. 2006;129(2):162-8. [pmid: 16675091].
82 Lim Y, Teoh W, Sia A. Combined spinal epidural does not cause a higher sensory block than single shot spinal technique for casarean delivery in laboring women. Anesth Analg. 2006;103(6):1540-2. [pmid: 17122236].
83 Lim Y, Sia A, Ho K, Teo A. Combined spinal epidural analgesia for labor with and without 3 ml of 1.5% epidural lidocaine. Med Sci Monit. 2006;13(1):CR9-CR13. [pmid: 17179911].
84 Lin S, Huang C, Lin H, et al. A Modified Goal-Directed Protocol Improves Clinical Outcomes in Intensive Care Unit Patients With Septic Shock: A Randomized Controlled Trial. Shock. 2006;26(6):551-7. [pmid: 17117128].
85 Liu X, Dong J, Mavrakis H, et al. Achievement of Pulmonary Vein Isolation in Patients Undergoing Circumferential Pulmonary Vein Ablation: A Randomized Comparison Between Two Different Isolation Approaches. J Cardiovasc Electrophysiol. 2006;17(12):1263-70. [pmid: 17239094].
86 Loprinzi C, Kugler J, Barton D, et al. Phase III Trial of Gabapentin Alone or in Conjunction With an Antidepressant in the Management of Hot Flashes in Women Who Have Inadequate Control With an Antidepressant Alone: NCCTG N03C5. J Clin Oncol. 2006;25(3):308-12. [pmid: 17146104].
87 Luanratanakorn P, Ratanapakorn T, Suwan-apichon O, et al. Randomised controlled study of conjunctival autograft versus amniotic membrane graft in pterygium excision. Br J Ophthalmol. 2006;90(12):1476-80. [pmid: 16837545].
88 Ludtke R, Albrecht U, Stange R, Uehleke B. Brachialgia paraesthetica nocturna can be relieved by “wet cupping”—–Results of a randomised pilot study. Complement Ther Med. 2006;14(4):247-53. [pmid: 17105694].
89 MacArthur R, Novak R, Peng G, et al. A comparison of three highly active antiretroviral treatment strategies consisting of non-nucleotide reverse transciptase inhibitors, protease inhibitors, or both in the presence of nucleoside reverse transcriptase inhibitors as initial therapy (CPCRA 058. Lancet. 2006;368(9553):2125-35. [pmid: 17174704].
90 Magliano L, Fiorillo A, Malangone C, et al. Patient functioning and family burden in a controlled, real-world trial of family psychoeducation for schizophrenia. Psychiatr Serv. 2006;57(12):1784-91. [pmid: 17158495].
91 Makrakis E, Angeli I, Agapitou K, et al. Laser versus mechanical assisted hatching: a prospective study of clinical outcomes. Fertil Steril. 2006;86(6):1596-600. [pmid: 17055494].
92 Malaguarnera M, Pistone G, Astuto M, et al. Effects of l-Acetylcarnitine on Cirrhotic Patients with Hepatic Coma: Randomized Double-Blind, Placebo-Controlled Trial. Dig Dis Sci. 2006;51(12):2242-7. [pmid: 17080254].
93 Manalakopoulos S, Economou M, Bethanis S, et al. A single alcohol ingestion does not affect serum hepatitis C virus RNA in patients with chronic hepatitis C. Liver Int. 2006;26(10):1196-200. [pmid: 17105584].
94 Marcora S, Chester K, Mittal G, Lemmey A, Maddison P. Randomized phase 2 trial of anti-tumor necrosis factor therapy for cachexia in patients with early rheumatoid arthritis. Am J Clin Nutr. 2006;84(6):1463-72. [pmid: 17158431].
95 Marsh A, Finger E, Buzas B, et al. Impaired recognition of fear facial expressions in 5-HTTLPR S-polymorphism carriers following tryptophan depletion. Psychopharmacology (Berl). 2006;189(3):387-94. [pmid: 17013635].
96 Martinez-Mier G, Mendez-Lopez M, Budar-Fernandez L, et al. Living related kidney transplantation without calcineurin inhibitors: initial experience in a Mexican center. Transplantation. 2006;82(11):1533-6. [pmid: 17164728].
97 Martoni A, Pinto C, Di Fabio F, et al. Capecitabine plus oxaliplatin (xelox) versus protracted 5-fluorouracil venous infusion plus oxaliplatin (pvifox) as first-line treatment in advanced colorectal cancer: A GOAM phase II randomised study (FOCA trial). Eur J Cancer. 2006;42(18):3161-8. [pmid: 17098421].
98 Mazzaferro V, Romito R, Schiavo M, et al. Prevention of hepatocellular carcinoma recurrence with alpha-interferon after liver resection in HCV cirrhosis. Hepatology. 2006;44(6):1543-54. [pmid: 17133492].
99 Mentzer R, Mehmet C, Sladen R, et al. Effects of perioperative nesiritide in patients with left ventricular dysfunction undergoing cardiac surgery. The NAPA trial. J Am Coll Cardiol. 2007;49(6):716-26. [pmid: 17291938].
100 Middleton F, Coakes J, Umarji S, et al. The efficacy of intra-articular bupivacaine for relief of pain following arthroscopy of the ankle. J Bone Joint Surg Br. 2006;88 - B(12):1603-5. [pmid: 17159171].
101 Miwa H, Osada T, Nagahara A, et al. Effect of a gastro-protective agent, rebamipide, on symptom improvement in patients with functional dyspepsia: A double-blind placebo-controlled study in Japan. J Gastroenterol Hepatol. 2006;21(12):1826-31. [pmid: 17074021].
102 Montgomery M, Hakanson B, Ljungqvist O, Ahlman B, Thorell A. Twelve months' follow-up after treatment with the EndoCinch endoscopic technique for gastro-oesophageal reflux disease: A randomized, placebo-controlled study. Scand J Gastroenterol. 2006;41(12):1382-9. [pmid: 17101568].
103 Moschonis G, Manios Y. Skeletal site-dependent response of bone mineral density and quantitative ultrasound parameters following a 12-month dietary intervention using dairy products fortified with calcium and vitamin D: the Postmenopausal Health Study. Br J Nutr. 2006;96(6):1140-8. [pmid: 17181890].
104 Neumeister A, Carson R, Henry S, et al. Cerebral metabolic effects of intravenous glycine in healthy human subjects. J Clin Psychopharmacol. 2006;26(6):595-9. [pmid: 17110816].
105 Ng K, Tsou M, Chao Y, et al. Urinary Catherization may not be necessary in minor surgey under spinal anesthesia with long actinglocal anesthetics. Acta Anaesthesiol Taiwan. 2006;44(4):199-204. [pmid: 17233363].
106 Niwa H, Tanimoto A, Sugimura M, Morimoto Y, Hanamoto H. Cardiovascular effects of epinephrine under sedation with nitrous oxide, propofol, or midazolam. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 2006;102(6):e1-e9. [pmid: 17138156].
107 Nohria A, Grunert M, Rikitake Y, et al. Rho Kinase Inhibition Improves Endothelial Function in Human Subjects With Coronary Artery Disease. Circ Res. 99(12):1426-32. [pmid: 17095725].
108 Odegaard S, Saether E, Steen P, Wik L. Quality of lay person CPR performance with compression:ventilation ratios 15:2, 30:2 or continuous chest compressions without ventilations on manikins. Resuscitation. 2006;71(3):335-40. [pmid: 17069958].
109 Offenbacher S, Lin D, Strauss R, et al. Effects of periodontal therapy during pregnancy on periodontal status, biologic parameters, and pregnancy outcomes: a pilot study. J Periodontol. 2006;77(12):2011-24. [pmid: 17209786].
110 Ohmit S, Victor J, Rotthoff J, et al. Prevention of Antigenically Drifted Influenza by Inactivated and Live Attenuated Vaccines. N Engl J Med. 2006;355(24):2513-22. [pmid: 17167134].
111 Olsen E, Hordinsky M, Whiting D, et al. The importance of dual 5a-reductase inhibition in the treatment of male pattern hair loss: Results of a randomized placebo-controlled study of dutasteride versus finasteride. J Am Acad Dermatol. 2006;55(6):1014-23. [pmid: 17110217].
112 Oosterheert J, Bonten M, Schneider M, et al. Effectiveness of early switch from intravenous to oral antibiotics in severe community acquired pneumonia: multicentre randomised trial. BMJ. 2006;333(7580):1193. [pmid: 17090560].
113 Orban J, Levraut J, Gindre S, et al. Effects of acetylcysteine and ischaemic preconditioning on muscular function and postoperative pain after orthopaedic surgery using a pneumatic tourniquet. Eur J Anaesthesiol. 2006;23(12):1025-30. [pmid: 16780616].
114 Ottermo M, Ovstedal M, Lango T, et al. The role of tactile feedback in laparoscopic surgery. Surg Laparosc Endosc Percutan Tech. 2006;16(6):390-400. [pmid: 17277655].
115 Ouyang P, Tarfif J, Herrington D, et al. Randomized trial of hormone therapy in women after coronary bypass surgery: Evidence of differential effect of hormone therapy on angiographic progression of disease in saphenous vein grafts and native coronary arteries. Atherosclerosis. 2006;189(2):375-86. [pmid: 16442114].
116 Panici P, Plotti F, Zullo M, et al. Pelvic lymphadenectomy for cervical carcinoma: Laparotomy extraperitoneal, transperitoneal or laparoscopic approach? A randomized study. Gynecol Oncol. 2006;103(3):859-64. [pmid: 16806442].
117 Pappone C, Augello G, Sala S, et al. A Randomized Trial of Circumferential Pulmonary Vein Ablation Versus Antiarrhythmic Drug Therapy in Paroxysmal Atrial Fibrillation. J Am Coll Cardiol. 2006;48(11):2340-7. [pmid: 17161267].
118 Parish L, Jorizzo J, Breton J, et al. Topical retapamulin ointment (1%, wt/wt) twice daily for 5 days versus oral cephalexin twice daily for 10 days in the treatment of secondarily infected dermatitis: Results of a randomized controlled trial. J Am Acad Dermatol. 2006;55(6):1003-13. [pmid: 17097398].
119 Patkar A, Masand P, Pae C, et al. A Randomized, Double-blind, Placebo-controlled Trial of Augmentation With an Extended Release Formulation of Methylphenidate in Outpatients With Treatment-Resistant Depression. J Clin Psychopharmacol. 2006;26(6):653-6. [pmid: 17110825].
120 Pelliccia F, Pasceri V, Granatelli A, et al. Safety and efficacy of short-term celecoxib before elective percutaneous coronary intervention for stable angina pectoris. Am J Cardiol. 2006;98(11):1461-3. [pmid: 17126650].
121 Peng H, Xu A. Colonic exclusion and combined therapy for refractory constipation. World J Gastroenterol. 2006;12(48):7864-8. [pmid: 17203535].
122 Pettigrew L, Kasner S, Gorman M, et al. Effect of arundic acid on serum S-100? in ischemic stroke. J Neurol Sci. 2006;251(1-2):57-61. [pmid: 17092520].
123 Pialoux V, Mounier R, Ponsot E, et al. Effects of exercise and training in hypoxia on antioxidant/pro-oxidant balance. Eur J Clin Nutr. 2006;60(12):1345-54. [pmid: 16788711].
124 Pierce J, Clark B, Ploutz-Snyder L, Kanaley J. Growth hormone and muscle function responses to skeletal muscle ischemia. J Appl Physiol. 2006;101(6):1588-95. [pmid: 16888046].
125 Pronyk P, Hargreaves J, Kim J, et al. Effect of a structural intervention for the prevention of intimate-partner violence and HIV in rural South Africa: a cluster randomised trial. Lancet. 2006;368(9551):1973-83. [pmid: 17141704].
126 Riiser A, Tjorhom A, Carlsen K. The effect of formoterol inhalation on endurance performance in hypobaric conditions. Med Sci Sports Exerc. 2006;38(12):2132-7. [pmid: 17146320].
127 Robinson D, Woerner M, Napolitano B, et al. Randomized comparison of olanzapine versus risperidone for the treatment of first-episode schizophrenia: 4-month outcomes. Am J Psychiatry. 2006;163(12):2096-102. [pmid: 17151160].
128 Rooke S, Malouff J. The Efficacy of Symbolic Modeling and Vicarious Reinforcement in Increasing Coping-Method Adherence. Behav Ther. 2006;37(4):406-15. [pmid: 17071217].
129 Saari T, Uvehammer J, Carlsson L, Regner L, Karrholm J. Posterior stabilized component increased femoral bone loss after total knee replacement. 5-year follow-up of 47 knees using dual energy x-ray absorptiometry. Knee. 2006;13(6):435-9. [pmid: 17011781].
130 Saiki A, Ohira M, Endo K, et al. The angiotensin II receptor antagonist valsartan enhances lipoprotein lipase mass in preheparin serum in type 2 diabetes with hypertension. Diabetes Res Clin Pract. 2006;74(3):242-8. [pmid: 16713009].
131 Salvadori M, Budde K, Charpentier B, et al. FTY720 versus MMF with Cyclosporine in de novo Renal Transplantation: A 1-Year, Randomized Controlled Trial in Europe and Australasia. Am J Transplant. 2006;6(12):2912-21. [pmid: 17061999].
132 Sand P, Goldberg R, Dmochowski R, McIlwain M, Dahl N. The impact of the overactive bladder syndrome on sexual function: A preliminary report from the Multicenter Assessment of Transdermal Therapy in Overactive Bladder with Oxybutynin trial. Am J Obstet Gynecol. 2006;195(6):1730-5. [pmid: 17132474].
133 Sandler A, Gray R, Perry M, et al. Paclitaxel–Carboplatin Alone or with Bevacizumab for Non–Small-Cell Lung Cancer. N Engl J Med. 2006;355:2542-50. [pmid: 17167137].
134 Schmittel A, Schmidt-Hieber M, Martus P, et al. A randomized phase II trial of gemcitabine plus treosulfan versus treosulfan alone in patients with metastatic uveal melanoma. Ann Oncol. 2006;17(12):1826-9. [pmid: 16971664].
135 Shah H, Hedge S, Shah J, et al. A prospective, randomized trial evaluating the safety and efficacy of fibrin sealant in tubeless percutaneous nephrolithotomy. J Urol. 2006;176(6 Pt 1):2488-92. [pmid: 17085137].
136 Shim J, Choi Y, Oh Y, et al. Effect of oral sildenafil citrate on intraoperative hemodynamics in patients with pulmonary hypertension undergoing valvular heart surgery. J Thorac Cardiovasc Surg. 2006;132(6):1420-5. [pmid: 17140970].
137 Shiver S, Blaivas M, Lyon M. A Prospective Comparison of Ultrasoundguided and Blindly Placed Radial Arterial Catheters. Acad Emerg Med. 2006;13(12):1275-9. [pmid: 17079789].
138 Simons L, Amansec S, Conway P. Effect of Lactobacillus fermentum on serum lipids in subjects with elevated serum cholesterol. Nutr Metab Cardiovasc Dis. 2006;16(8):531-5. [pmid: 17126768].
139 Sipe C, Davis W, Maifeld M, van Voorhis B. A prospective randomized trial comparing anastrozole and clomiphene citrate in an ovulation induction protocol using gonadotropins. Fertil Steril. 2006;86(6):1676-81. [pmid: 17007849].
140 Sprigg N, Bath P, Zhao L, et al. Patients With Subacute Ischemic Stroke: The Stem Cell Trial of Recovery Granulocyte-Colony-Stimulating Factor Mobilizes Bone Marrow Stem Cells in Patients With Subacute Ischemic Stroke: The Stem Cell Trial of Recovery EnhanceMent After Stroke (STEMS) Pilot Randomized, Controlled Trial. Stroke. 2006;37(12):2979-83. [pmid: 17082474].
141 Steinkruger G, Nusstein J, Reader A, Beck M, Weaver J. The significance of needle bevel orientation in achieving a successful inferior alveolar nerve block. J Am Dent Assoc. 2006;137(12):1685-91. [pmid: 17138713].
142 Tamer C, Oksuz H. Circadian intraocular pressure control with dorzolamide versus timolol maleate add-on treatments in primary open-angle glaucoma patients using latanoprost. Ophthalmic Res. 2006;39(1):24-31. [pmid: 17164574].
143 Tan K, Sng K, Tay K, Lai J, Eu K. Randomized clinical trial of 0·2 per cent glyceryl trinitrate ointment for wound healing and pain reduction after open diathermy haemorrhoidectomy. Br J Surg. 2006;93(12):1464-8. [pmid: 17115390].
144 Thorburn M, Vistisen B, Thorp R, et al. Attenuated gastric distress but no benefit to performance with adaptation to octanoate-rich esterified oils in well-trained male cyclists. J Appl Physiol. 2006;101(6):1733-43. [pmid: 16840580].
145 Uebelacker L, Beevers C, Battle C, et al. Family Functioning in Bipolar I Disorder. J Fam Psychol. 2006;20(4):701-4. [pmid: 17176206].
146 Ullenhang G, Spendlove I, Watson N, et al. A Neoadjuvant/Adjuvant RandomizedTrial of Colorectal Cancer PatientsVaccinated with an Anti-Idiotypic Antibody, 105AD7,Mimicking CD55. Clin Cancer Res. 2006;12(24):7389-96. [pmid: 17121873].
147 Umemura T, Ueda K, Nishioka K, et al. Effects of Acute Administration of Caffeine on Vascular Function. Am J Cardiol. 2006;98(11):1538-41. [pmid: 17126666].
148 Unlugenc H, Ozalevli M, Gunes Y, et al. A double-blind comparison of intrathecal S(+) ketamine and fentanyl combined with bupivacaine 0.5% for Caesarean delivery. Eur J Anaesthesiol. 2006;23(12):1018-24. [pmid: 16824240].
149 van den Berg M, Ronday H, Peeters A, et al. Using Internet Technology to Deliver a Home-Based Physical Activity Intervention for Patients With Rheumatoid Arthritis: A Randomized Controlled Trial. Arthritis Rheum. 2006;55(6):935-45. [pmid: 17139640].
150 van Osterhout M, Sont J, Bajema I, Breedveld F, van Laar J. Comparison of Efficacy of Arthroscopic Lavage Plus Administration of Corticosteroids, Arthroscopic Lavage Plus Administration of Placebo, and Joint Aspiration Plus Administration of Corticosteroids in Arthritis of the Knee: A Randomized Controlled Trial. Arthritis Rheum. 2006;55(6):964-70. [pmid: 17139644].
151 Van K, Hides J, Richardson C. The Use of Real-Time Ultrasound Imaging for Biofeedback of Lumbar Multifidus Muscle Contraction in Healthy Subjects. J Orthop Sports Phys Ther. 2006;36(12):920-5. [pmid: 17193869].
152 Vas J, Perea-Milla E, Mendez C, et al. Efficacy and safety of acupuncture for chronic uncomplicated neck pain: a randomised controlled study. Pain. 2006;126(1-3):245-55. [pmid: 16934402].
153 Vassallo B, Culpepper C, Segal J, Moen M, Noone M. A randomized trial comparing methods of vaginal cuff closure at vaginal hysterectomy and the effect on vaginal length. Am J Obstet Gynecol. 2006;195(6):1805-8. [pmid: 17132483].
154 Vertigan A, Theodoros D, Gibson P, et al. Efficacy of speech pathology management for chronic cough: a randomized placebo controleld trial of treatment efficacy. Thorax. 2006;61(12):1065-9. [pmid: 16844725].
155 Vollmer W, Kirschner M, Peters D, et al. Use and Impact of an Automated Telephone Outreach System for Asthma in a Managed Care Setting. Am J Manag Care. 2006;12(12):725-33. [pmid: 17149995].
156 Wang G, Li T, Wang L, et al. Tong-xie-ning, a Chinese herbal formula, in treatment of diarrhea-predominant irritable bowel syndrome: a prospective, randomized, double-blind, placebo-controlled trial. Chin Med J. 2006;119(24):2114-9. [pmid: 17199964].
157 Wang S, Hu Z, Li S, Huang X, Ye C. Effect of external valvuloplasty of the deep vein in the treatment of chronic venous insufficiency of the lower extremity. J Vasc Surg. 2006;44(6):1296-300. [pmid: 17145434].
158 Watson A, El-Deredy W, Bentley D, Vogt B, Jones A. Categories of placebo response in the absence of site-specific expectation of analgesia. Pain. 2006;126(1-3):115-22. [pmid: 16890357].
159 Webster L, Butera P, Moran L, et al. Oxytrex Minimizes Physical Dependence While Providing Effective Analgesia: A Randomized Controlled Trial in Low Back Pain. J Pain. 2006;7(12):937-46. [pmid: 17157780].
160 Weiss J, Shavin J, Nighland M, Grossman R. Tretinoin microsphere gel 0.1% for photodamaged facial skin: a placebo-controlled trial. Cutis. 2006;78(6):426-32. [pmid: 17243432].
161 Wiggers L, Smets E, Oort F, et al. The effect of a minimal intervention strategy in addition to nicotine replacement therapy to support smoking cessation in cardiovascular outpatients: a randomized clinical trial. Eur J Cardiovasc Prev Rehabil. 2006;13(6):931-7. [pmid: 17143125].
162 Yu D, Murdoch S, Parikh S, et al. Rosiglitazone increases LDL particle size and buoyancy and decreases C-reactive protein in patients with type 2 diabetes on statin therapy. Diab Vasc Dis Res. 2006;3(3):189-96. [pmid: 17160915].