# Appendixes

Appendix A Sample of Randomized Controlled Trials

Appendix B Guidelines for Risk of Bias Assessments

Appendix C Variables for Data Extraction from Randomized Controlled Trials

Appendix D Meta-Analyses and Cohort Studies Used for NOS Assessments

Appendix E Decision Rules for Application of the Newcastle-Ottawa Scale

Appendix F Supplementary Information for NOS Assessments

Appendix G Description of Randomized Controlled Trials

Appendix H Data Used for Kappa Calculations

Appendix I Inter-rater Reliability on Risk of Bias Assessments, by Domain and Study-level Variable With Confidence Intervals

Appendix J Sources of Disagreement Across Consensus Assessments Using the Risk of Bias Tool