# Acknowledgments

The authors gratefully acknowledge the following individuals from the University of Alberta (U of A) EPC, University of Ottawa (U of O) EPC, McMaster EPC, and South California (SC)/RAND EPC for assisting with risk of bias and/or quality assessments: Susan Armijo Olivo (U of A), Christine Ha (U of A), Chantelle Garritty (U of O), Homa Keshavarz (McMaster), Kristin Konnyu (U of O), Dunsi Oladel-Rabiu (U of A), Alicia Ruelaz (SC/RAND), Larissa Shamseer (U of O), Kavita Singh (U of O), Elizabeth Sumamo (U of A), Jennifer Tetzlaff (U of O), Lucy Turner (U of O), Zhen Wang (SC/RAND), Fatemeh Yazdi (U of O). We thank Annabritt Chisholm from the U of A EPC for technical assistance in preparing the report. We thank Dr. Sally Hopewell for providing the list of randomized controlled trials from which we drew our sample.