# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CERs: Comparative Effectiveness Reviews
CHIP: Children's Health Insurance Program
EHC: Effective Health Care
EPC: Evidence-based Practice Center
ES: effect size(s)
I^2^: I-squared
ICC: intra-class correlation
IQR: inter-quartile range
NOS: Newcastle Ottawa Scale
RCTs: randomized controlled trials
ROB: risk of bias
ROR: ratio of odds ratios
SR: systematic review