# References

1 French SD, McDonald S, McKenzie JE, et al. Investing in updating: how do conclusions change when Cochrane systematic reviews are updated?. BMC Med Res Methodol. 2005;5:33. [pmid: 16225692].
2 Gartlehner G, West SL, Lohr KN, et al. Assessing the need to update prevention guidelines: a comparison of two methods. Int J Qual Health Care. Oct. 2004;16(5):399-406. [pmid: 15375101].
3 Moher D, Tsertsvadze A, Tricco AC, et al. When and how to update systematic reviews. Cochrane Database Syst Rev. 2008;(1):MR000023. [pmid: 18254126].
4 Peterson K, McDonagh MS, Fu R. Decisions to update comparative drug effectiveness reviews vary based on type of new evidence. J Clin Epidemiol. Sep. 2011;64(9):977-84. [pmid: 21411283].
5 Shekelle P, Eccles MP, Grimshaw JM, et al. When should clinical guidelines be updated?. BMJ. Jul. 21. 2001;323(7305):155-7. [pmid: 11463690].
6 Shojania KG, Sampson M, Ansari MT, et al. How quickly do systematic reviews go out of date? A survival analysis. Ann Intern Med. Aug. 21. 2007;147(4):224-33. [pmid: 17638714].
7 Tsertsvadze A, Maglione M, Chou R, et al. Updating comparative effectiveness reviews: current efforts in AHRQ's Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1208-15. [pmid: 21684114].
8 Marcy M, Takata G, Chan LS, et al. Management of acute otitis media. Evid Rep Technol Assess (Summ). Jun. 2001;(15):1-4. [pmid: 10932957].
9 Shekelle PG, Takata G, Newberry SJ, et al. Management of Acute Otitis Media: update. Evid Rep Technol Assess (Full Rep). Nov. 2010;(198):1-426. [pmid: 23126594].
10 Crandall CJ, Newberry SJ, Diamant A, et al. Comparative Effectiveness of Treatment to Prevent Fractures in Men and Women with Low Bone Density or Osteoporosis- Update. Evidence Report/Technology Assessment No. 53. (Prepared by the Sothern California Evidence-based Practice Center under Contract No. HHSA290200710062I). Rockville, MD. Agency for Healthcare Research and Quality. http://effectivehealthcare.ahrq.gov/ehc/products/160/1007/CER-53_LowBoneDensity_FinalReport_20120501.pdf 2012 Mar Osteoporosis: Update of a 2007 Report. [pmid: 22553885].