# Methods

To conduct this study, we identified the relevant groups of stakeholders, solicited one or two members of each of these groups with whom we had worked on previous occasions or based on word-of-mouth recommendations, and asked them if they would be willing to participate in small focus groups or one-on-one sessions to evaluate several mechanisms for presenting update reports. We then identified various formats used to present update reports and reformatted the executive summary of a CER we had updated in 2009 to conform to these various formats. Finally, we presented the executive summary in a number of different formats to each of two informal focus groups and three individual providers and asked them to review the summaries and complete a brief questionnaire. We then convened the members of each focus group and asked them for any further input.

## Identification of Stakeholders/Users of Comparative Effectiveness Reviews

Based on our experiences identifying and working with stakeholders on a number of CERs covering a variety of topics (including management of acute otitis media, prevention and treatment of osteoporosis, use of omega-3-fatty acid supplements for the prevention of chronic conditions, and off-label uses of newer antipsychotic medications), as well as our experiences assessing the need to update AHRQ's portfolio of CERs, we initially identified five categories of users: private insurers (payers), health plan administrators, professional practice organizations that establish practice guidelines, academic researchers and physicians, and health communicators. Although we also consider consumers to be potential users of evidence review findings, we did not include consumers in our focus groups, because the Eisenberg Center is responsible for translating the findings of evidence reviews for consumer needs. We then contacted individuals who had served on technical expert panels as well as several former RAND and SCEPC core staff and others recommended by colleagues to ask if they would be willing to participate in an informal virtual focus group to assess various formats for presenting the results of updates of evidence reviews. During our first focus group, we asked the participants for suggestions of additional categories of potential users of the results of evidence reviews; they suggested we convene a group of Federal and municipal policymakers as well as a group of community physicians who were not affiliated with a medical school.

## The Report Formats

In 2009, our EPC conducted an evidence review to update the findings of a review we had conducted in 2001 on management of acute otitis media, similar to a CER.8,9 We used the executive summaries of the original and update reports to create summaries in five different formats (shown in Appendix C), intending that these summaries should be complete enough to serve as standalone products for users with relatively basic informational needs (to the same extent that we now expect the executive summaries of EPC evidence reviews to stand alone).

Version 1. For this version, we began with the text of the 2001 executive summary (See Appendix C). We made only the minimal number of necessary changes (i.e., revising the search start and end dates, changing effect sizes and confidence intervals for drug comparisons analyzed in both reports, and adding text to report the results of new comparisons and the findings for a new Key Question). We did not highlight these changes in any way. This version replicated a format used by one of the existing organizations dedicated to conducting systematic reviews of the evidence.

Version 2. For version 2, we highlighted in gray the changes we had made to create version 1 (See Appendix C). This version replicated the format used by another organization that conducts systematic reviews.

Version 3. For version 3, we revised the text of the original 2001 executive summary to match the 2009 executive summary using “track changes” to highlight the deletions and additions (See Appendix C). However this version lacked a set of summary tables that was included in the actual 2009 version. These tables are described below for version 4.

Version 4. Version 4 was the actual executive summary for the 2009 report (See Appendix C). In addition to providing narrative text, to compare the updated meta-analytic findings on the effectiveness and safety of pharmacological treatments to the 2001 findings, we constructed tables that showed the pooled effect sizes and total numbers of studies for each drug or drug combination from 2001 and 2009, along with our conclusions. For drugs for which no new—or no previous—studies were identified, we simply presented the existing data and noted that no comparison was possible.

Version 5. For version 5, we reformatted the summary tables presented in version 4, so that instead of presenting the actual pooled effect sizes, the tables described the changes from 2001 to 2009 in narrative text (see Appendix C). The reason for including this version was to simulate the way we presented comparative results for an update CER report that included almost no meta-analyses and for which most of the results needed to be described narratively, as was the case for the update of the CER on prevention and treatment of osteoporosis.10

Revisions to these versions for subsequent focus groups are described below.

## The Questionnaire and Focus Groups

### Focus Group 1

Approximately 4 weeks prior to the week we hoped to hold our first virtual focus group (via conference call), we contacted eight potential participants, providing a description of the project and querying them regarding their willingness to participate in exchange for a small honorarium ($200, although we did not specify the amount). Only one declined to participate, citing a timing conflict; we scheduled the focus group at a time convenient to the seven who agreed to participate. Thus, the first focus group comprised the director of research for a large private insurer; a physician/administrator for a large health maintenance organization; a clinician in an academic medical center with experience conducting and using evidence reviews; two physicians who led and participated in, respectively, the revision of a set of guidelines for a major professional practice organization; a research assistant involved in guidelines setting; and a staff member of RAND's Office of External Affairs.

One week prior to the first focus group, in April 2011, we sent the five versions of the executive summary to the seven participants with additional background on the project and a brief questionnaire (Appendix A), asking for their feedback on the various differences among the five versions and their assessments of the utility (using a 5-point Likert scale but also allowing for free text comments). We asked that they return the completed questionnaires by the day before the scheduled call. All participants returned their completed questionnaires. We compiled the responses, anonymously in PowerPoint slides. During the call, we shared the results and asked for further feedback and comments, including any suggestions the group had regarding additional kinds of potential users we should include in a future focus group. The group suggested we conduct a focus group among government policymakers. One member of the group, the HMO physician/administrator, also provided us with a sample of a summary of an updated evidence review his organization had prepared to support a set of treatment guidelines the HMO providers were expected to follow (see description below).

### Focus Group 2

In September 2011, based on the suggestions of the first focus group participants, we elicited opinions from a number of Federal and municipal health policymakers with whom we had worked in the past regarding their willingness to participate in a focus group. The resulting group comprised a director of an office at the Food and Drug Administration (FDA) and editor in chief of a major journal, the director of a U.S. Department of Agriculture-funded university research center, an FDA staff scientist whose research group cosponsored a previous evidence review, a researcher involved in policymaking at the Centers for Medicare & Medicaid Services, and a former congressional staffer with experience in health policy. This focus group was conducted identically to the first one (see Appendix B for questionnaire).

### Focus Group 3

We then intended to run a third focus group comprising community primary care physicians with no academic appointments. We contacted eight physicians, seven suggested by a member of Focus Group 1, and one suggested by one of the project staff. Only four of eight physicians contacted responded, and of those, only three agreed to participate. Within the timeline for this project, we were unable to identify a time that was mutually agreeable for these three individuals to meet. Therefore, to complete the project on time, we elected to communicate with them individually, sending the materials (the most recent four versions of the executive summary and the questionnaire) and following up to clarify responses to the questionnaire.