# The 7 Versions of the Executive Summary for Which We Elicited Focus Group Feedback

This appendix presents each version of the executive summary that was provided to the focus groups for their feedback.

Version 1 modified the executive summary included in the original 2001 Acute Otitis Media management report to include the findings in the 2008 update report but did not indicate the changes to the text or the new findings.

Version 2 highlighted the text changes and new findings presented in version 1.

Version 3 tracked the changes from the original to arrive at Version 1 using underlining and strikethrough.

Version 4 is the executive summary included in the update report. It is entirely new text and does not use formatting elements to call attention to the changes (new Key Questions, new findings). However, this version includes tables that compare the numbers of studies and the effect sizes from the original report with the numbers of studies and effect sizes of old and new studies combined, for efficacy and safety.

Version 5 includes the same text as version 4 but instead of the quantitative comparison tables, it includes tables that narratively compare the findings of the old and new reports.

Version 6 combines versions 4 and 5 (both quantitative and narrative tables).

Version 7 contains almost no narrative text. The Key Questions, conceptual framework, search strategy, inclusion and exclusion criteria, and findings are presented graphically.

Version 1

Version 2

Version 3

Version 4

Version 5

Version 6 (“New” Version 3) Used for Focus Group 2 and Community Physicians

Version 7 (“New” Version 4) Used for Focus Group 2 and Community Physicians