# Focus Group Questionnaire 1

Overview

The updating of evidence reports is becoming more common, and various approaches are being used to present the updates. However, there is little research about which approach(s) would be most useful to policymaking and provider audiences as they use the new report. The goal of this project is to gather qualitative evidence about the usefulness of several different approaches. The purpose of this questionnaire is to get some initial reactions to several approaches, which we will then use as a starting point for our discussion on April 27.

First let us explain the sample formats that we have developed. We have provided 5 versions of an executive summary for the update of an evidence review on management of acute otitis media in children. These are representative of actual practices used by various review groups.

1. Version 1 does not call attention in any way to what has changed from the original report to the update report. The implication of this approach is that all of the findings in this document are up-to-date as of the end date of the search.
2. Version 2 uses gray shading to indicate new text (including new questions not addressed in the original report) and new findings.
3. Version 3 is a track-changes version. It shows explicitly what has changed from the original report by underlining new material and scoring through material that was replaced.
4. Version 4 does not follow the structure of the original report; it was drafted expressly for the update report. It explicitly compares the key quantitative findings of the update review with those of the original review in two tables (one for drug effects, one for adverse events).
5. Version 5 is identical to version 4 except that instead of the two quantitative tables, it contains one table that compares all the results of the old and new report in narrative format.

To get started, first tell us on a scale of 1-5 (where 1 is not important and 5 is very important) how important you think it is to know what has changed from the previous version of the report. (If knowing what has changed is important, then you will find version 1 to be less useful than versions 2, 3, 4, or 5.) Please circle appropriate response. 1 2 3 4 5

Suppose it has been determined that indicating new material in the update report is important. Please tell us how helpful you would find the following approaches to indicating new material, keeping in mind how you would typically be using the update report.

Approach | Not helpful | | | | Very helpful
Grey shading to indicate new material? (Version 2).
- Would the shading be more useful if only the quantitative findings changed but all the questions remained the same?
New material underlined; old material crossed out. (Version 3) Is it helpful to see the new findings in the context of the previous ones?
Versions 4 and 5: In general, it is helpful to have the previous and new findings explicitly compared?
How helpful are the tables in Version 4, which explicitly compare the quantitative findings of the two reports?
- How helpful would it be to have this kind of table in Versions 1, 2, or 3?
How helpful is the single narrative table that includes both quantitative and qualitative findings? (Version 5)
- Would the narrative table be more useful if the report had only qualitative findings (i.e., no meta-analysis)?
- How helpful would it be to include this kind of narrative table in versions 1, 2, or 3?

- Can you suggest other ways to emphasize the information that is important to you in an updated report?
- What guidance can you give us about how to test these, or other approaches, with a broader audience?

To help us understand your responses better, we would appreciate your answering a few questions about yourself:

- What is your current position?
- In general, how important are evidence reviews to you in making the kinds of decisions for which you are responsible?
- Have you ever worked on an evidence review?