# Introduction

Comparative reviews of the evidence on the effectiveness and safety of medications, medical devices, and care practices are increasingly relied upon to establish policies and guidelines aimed at improving the quality and cost-effectiveness of health care. Yet to remain useful to policymakers, health care providers, and other decisionmakers, comparative effectiveness reviews (CERs) and other systematic reviews of the evidence must be kept up to date. While a growing number of studies have examined how and when to conduct an update, less consideration has been given to the optimal presentation of the results of updated reviews for the various audiences who need to use this information.1-7 Organizations that traditionally conduct or commission evidence reviews and updates of these reviews rely on a variety of formats to present the results of updates. The formats used to highlight new sources, Key Questions or issues, search and analytic methods, findings, and conclusions—or to contrast the old with the new—vary depending on the organization and the format chosen. For example, one particular organization “highlights” new quantitative findings in gray (without showing the old findings), whereas another provides a table at the end of the report that lists methodological differences between current and prior reviews as well as newly included studies but does not include actual changes in findings.

In 2011, the Agency for Healthcare Research and Quality (AHRQ)'s Evidence-Based Practice Centers (EPC) program, anticipating the need to begin updating the CERs, asked the Southern California Evidence-based Practice Center at RAND to design a format for presenting the results of these update reports. The intent was to create a more or less standard format, recognizing that no one format would necessarily be appropriate for all types of reports or stakeholders. In other words, we hoped to identify a format that would be flexible enough to accommodate differences in the numbers and kinds of Key Questions asked and results obtained (e.g., reports with meta-analyses vs. those with only qualitative findings; reports with only 2 or 3 treatments vs. those with 20 different treatments and/or categories of patients). We also wished to accommodate differences in the information needs of various stakeholders as well as differences in their ways of accessing information.

To shed light on an ideal report format, we decided to assess the needs of users of CERs and their preferences for the formats used for update reports. This report summarizes the process used to identify and query stakeholders and the findings of this effort.