# Results and Conclusion

For each CER, we constructed summary tables that presented the evidence from the new searches, the expert responses, and an assessment regarding the need to update each conclusion. A summary of our findings is presented in Tables 2 and 3. In Table 2, we list the CER title and the number of conclusions assessed to still be valid. We also present the numbers of conclusions that are possibly or probably out of date, and definitely out of date, as well as the identification of potential safety issues and whether new evidence suggests a new indication for a treatment or a new treatment for an existing indication. Our overall assessment of the need for updating is shown in Table 3.

Table 2 Summary of Assessments

CER Title | Number of conclusions assessed | | | | Safety issue? | New indication for existing or new treatment
CER Title | Still valid | Possibly out of date | Probably out of date | Out of date | Safety issue? | New indication for existing or new treatment
Comparative Effectiveness of Management Strategies for Gastroesophageal Reflux Disease | 6 | 1 | 1 | 4 | Yes | Yes
Effectiveness of Noninvasive Diagnostic Tests for Breast Abnormalities | 1 | 2 | 1 | 0 | No | Yes
Comparative Effectiveness of Epoetin and Darbepoetin for Managing Anemia in Patients Undergoing Cancer Treatment | 2 | 3 | 2 | 1 | Yes | No
Comparative Effectiveness and Safety of Analgesics for Osteoarthritis | 20 | 4 | 1 | 2 | Yes | No
Efficacy and Comparative Effectiveness of Off-Label Use of Atypical Antipsychotics | 16 | 4 | 1 | 0 | No | Yes
Comparative Effectiveness of Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression | 13 | 7 | 0 | 0 | No | No
Comparative Effectiveness of Percutaneous Coronary Interventions and Coronary Artery Bypass Grafting for Coronary Artery Disease | 13 | 5 | 1 | 0 | No | No
Comparative Effectiveness of Angiotensin- Converting Enzyme Inhibitors (ACEIs) and Angiotensin II Receptor Antagonists (ARBs) for Treating Essential Hypertension | 7 | 1 | 0 | 0 | No | No
Comparative Effectiveness of Drug Therapy for Rheumatoid Arthritis and Psoriatic Arthritis in Adults | 14 | 4 | 1 | 1 | No | Yes
Comparative Effectiveness of Treatments To Prevent Fractures in Men and Women With Low Bone Density or Osteoporosis | 35 | 4 | 0 | 0 | No | Yes
Comparative Effectiveness of Therapies for Clinically Localized Prostate Cancer | 10 | 7 | 3 | 0 | No | No

Table 3 Assessments Concerning Need for Updating Reports

High Priority; - Comparative Effectiveness of Management Strategies for Gastroesophageal Reflux Disease; - Effectiveness of Noninvasive Diagnostic Tests for Breast Abnormalities; - Comparative Effectiveness of Epoetin and Darbepoetin for Managing Anemia in Patients Undergoing Cancer Treatment; - Comparative Effectiveness and Safety of Analgesics for Osteoarthritis
Medium Priority; - Efficacy and Comparative Effectiveness of Off-Label Use of Atypical Antipsychotics; - Comparative Effectiveness of Treatments To Prevent Fractures in Men and Women With Low Bone Density or Osteoporosis; - Comparative Effectiveness of Drug Therapy for Rheumatoid Arthritis and Psoriatic Arthritis in Adults; - Comparative Effectiveness of Therapies for Clinically Localized Prostate Cancer
Low Priority; - Comparative Effectiveness of Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression; - Comparative Effectiveness of Angiotensin-Converting Enzyme Inhibitors (ACEIs) and Angiotensin II Receptor Antagonists (ARBs) for Treating Essential Hypertension; - Comparative Effectiveness of Percutaneous Coronary Interventions and Coronary Artery Bypass Grafting for Coronary Artery Disease

This report is accompanied by three appendixes. Appendix I presents the findings of our searches of the literature, FDA MedWatch Database and expert assessments, along with our overall recommendation regarding updating for each of the CERs assessed, and the conclusion(s) on which each recommendation is based. Appendix II presents the evidence tables, and Appendix III presents the literature search strategies for each CER topic.

We would envision a regular process of surveillance that is organized like Figure 2 below.

Figure 2 Proposed Process for Assessment of Need for CER Update