# References

French SD, McDonald S, McKenzie JE, Green SD. Investing in updating: how do conclusions change when Cochrane systematic reviews are updated?. BMC Medical Research Methodology. October. 14. 2005;5:33. [pmid: 16225692].
Gartlehner G, West SL, Lohr KN, Kahwati L, Johnson JG, Harris RP, Voisin CE, Sutton S. Assessing the need to update prevention guidelines: a comparison of two methods. International Journal for Quality in Health Care. 2004;16(5):399-406. [pmid: 15375101].
Shekelle P, Eccles MP, Grimshaw JM, Woolf SH. When should guidelines be updated?. BMJ. July. 21. 2001;323(7305):155-7. [pmid: 11463690].
Shekelle P, Ortiz E, Rhodes S, Morton SC, Eccles MP, Grimshaw JM, Woolf SH. Validity of the Agency for Healthcare Research and Quality clinical practice guidelines: how quickly do guidelines become outdated?. JAMA. Sep. 26. 2001;286(12):1461-7. [pmid: 11572738].
Shojania KG, Sampson M, Ansari MT MBBS, Ji J, Doucette S, Moxher D. How quickly do systematic reviews go out of data: a survival analysis. Ann Intern Med. 2007;147:224-233. [pmid: 17638714].
Whitlock E. Challenges in Systematic Reviews— Can use Existing Reviews Save Time? Be Valid?. Presented at Annual EPC Meeting. July 11, 2008.