# Methods

Changes in the evidence underlying clinical guidelines and standards of care, i.e., contradictory or even confirming evidence from large well-designed studies published subsequent to the original systematic review, can have significant implications for those guidelines and for clinical and consumer decision-making. The rapidity with which new research findings accumulate makes it imperative that the evidence be assessed periodically to determine the need for a full-scale update. In early 2008, AHRQ determined that in order to meet their intended objectives the EHC Program should assess the need for the findings of the CERs completed to that point to be updated. The Southern California Evidence-based Practice Center (SCEPC) was tasked with conducting this assessment, that is, reviewing the literature and gathering expert opinion in support of this assessment.

The science of updating systematic reviews has been developing for the past decade. Prior to 2001, no method or criteria existed to determine whether evidence-based products remained valid or whether the evidence underlying them had been superseded by newer work. In the late 1990s, AHRQ asked the SCEPC to determine whether their clinical practice guidelines needed to be updated and how quickly guidelines go out of date. The SCEPC first devised a conceptual model that consisted of six situations that would require a guideline to be updated or withdrawn (Shekelle et al., 2001). These situations included changes in (1) the available interventions, (2) the evidence on the benefits and harms of existing interventions, (3) the outcomes that are considered important, (4) the evidence that current practice is optimal, (5) the values placed on outcomes, and (6) the resources available for health care. Their assessment of the need to update the AHRQ guidelines did not take the final two situations into account as the measurement of these situations was considered beyond the scope of the process. The mandate also required that, rather than conducting a series of new systematic reviews, the SCEPC would devise a method that could be feasibly applied to a large number of guidelines. Reasoning that any new findings that differed from the previous findings with sufficient magnitude to warrant reconsideration of a guideline would be both published in a major journal and familiar to experts in the field, they thus used a combination of a focused literature search and the guidance of experts from relevant disciplines as a more pragmatic way to help identify potentially significant new evidence. Using this approach, they determined that out of 17 guidelines, new evidence and expert assessment indicated that 7 required a major update; 6 were found to be in need of a minor update; 3 were assessed as still valid; and for 1 guideline, no conclusion could be reached. Survival analysis indicated that about half the guidelines were outdated in 5.8 years; at 3.6 years, no more than 90 percent of the guidelines were still valid. (Shekelle et al, 2001)

The Cochrane Collaboration has striven to update its systematic reviews biennially. However, such updates involve a huge investment of time and effort and might not be appropriate for all topics. Thus, in 2005, members of the Collaboration assessed whether 4-year updates might be adequate for some topics by comparing the results and conclusions of 1998 reviews with their 2002 updates. Among 254 updated reviews, only 23 (9%) had a change in conclusion, supporting the idea that a priority approach, rather than an automatic time-based approach, should be used to determine the need for an update (French et al., 2005).

Shojania and colleagues also devised a method—using survival analysis—to assess the need to update reviews and tested it among 100 meta-analyses published from 1995 to 2005. The method did not involve expert assessment, but instead relied on a combination of quantitative and qualitative analysis. The quantitative signal that a review was out-of-date was a change in statistical significance or relative effect size of at least 50 percent. Qualitative signals included major changes in the characterization of effectiveness, new information about adverse events, or some other warning about the reliability of previous findings. Among the 100 reviews (which ranged in age from approximately 1 to 10 years), 57% showed some sign of being out-of-date. The median length of survival without displaying such a signal was 5.5 years; although 7 percent of the reviews were out-of-date by the time they were published, only 4% were out of date within a year of the end of the search period. Thus, like the Shekelle study, this study showed the need for frequent, and in some cases almost immediate, updating. The apparent need for more frequent update was related to topic and to heterogeneity in the original report.

To compare the comprehensiveness and effort required to employ the SCEPC abbreviated method with that of a typical full-blown literature search, Gartlehner and colleagues (2004) at the University of North Carolina Chapel Hill and RTI first created a streamlined version of the SCEPC method. They then employed both to assess the need to update the 1996 US Preventive Services Task Force Guide to Clinical Preventive Services. The study found that although the abbreviated SCEPC method identified fewer eligible studies than the “traditional approach,” Task Force members who were acting as project liaisons rated none of the studies missed by the abbreviated method as important to assessing the need for an update to the guidelines. Thus they deemed the revised approach to be an efficient and acceptable method for assessing the need to update a guideline.